# Summary of Key Informant Interviews

What are the most commonly used imaging modalities to evaluate treatment of metastatic breast cancer?
- Choice of imaging strongly depends on where metastases are. If there are no boney metastases, would probably follow up with chest/abdomen/pelvis CT, but patients who had a baseline PET-CT are usually followed up with PET-CT also.
- MRI might be used on a patient with brain metastases, especially if they had a baseline scan.
- Most people use the Response Evaluation Criteria in Solid Tumors (RECIST) criteria to determine how well patients are responding to treatment, but the PET Response Criteria in Solid Tumors (PERCIST) is also used and may be more accurate.
- Use of PET-CT is extremely common because machines have been purchased and, once owned, might as well use them.

How often is imaging for treatment evaluation of metastatic breast cancer conducted?
- Usual assessment of metastatic disease involves a baseline PET-CT scan that could be repeated every 2-4 months, but if staging PET-CT is not covered by insurance, a bone scan or chest/abdomen/pelvis CT (or both) are often used.
- Imaging may be avoided if patient is displaying symptoms.
- The choice of imaging and intervals are often dictated by insurance coverage. PET-CT is not covered earlier than 2 month followup. Also, some plans require potentially time-consuming peer-to-peer discussions about whether PET-CT is warranted, so that discourages doctors from ordering it.
- Intervals of imaging depend on treatment cycles. Also, unlikely to see clinical progression before 2-3 months of treatment so most imaging is not ordered earlier than that.
- Patients can also experience anxiety about imaging so that's a reason to limit tests, but on the other hand, if tests show treatment is working, that is very heartening for patients.

When is PET-CT used versus bone scan?
- At baseline, PET-CT tends to find more lesions than bone scan; this usually doesn't affect treatment choice unless a bone lesion is found, since treating bone lesions has large effect on the patient's quality of life.
- PET-CT can help visualize followup of disease in difficult to visualize areas, such as nodes, or if anatomic alterations have occurred to the patient as a results of treatment.

Which imaging modalities are being over/under utilized?
- PET-CT probably less appropriately utilized because it is a newer technology. This is an active area of research.
- Some imaging is driven by pharmaceutical trials that dictate certain types of followup. This tends to become a familiar/usual approach in practice.

Differences in imaging use between academic versus community settings?
- Community practice seems to be more variable.
- Patient preparation and physician interpretation is often inferior in the community setting.
- Patient insurance status might come into play more often in community setting, e.g., patient without adequate insurance might be steered toward less expensive imaging.
- Physicians in academic settings may feel more pressure to use the most recent (and therefore most expensive) technologies. May have a greater fear of lawsuits if they fail to order a test.

What policies do payers put in place to influence use of imaging for treatment evaluation of metastatic breast cancer?
- Payers use Radiology Benefit Managers (RBMs) to encourage providers to minimize use of imaging, but not a lot of evidence behind their decisions.
- Payers require peer-to-peer consultations. Often does discourage imaging from being ordered but again, unclear whether this is appropriate.

How are decisions to purchase imaging equipment used to evaluate treatment for metastatic breast cancer made?
- Most cancer centers have CT and PET-CT because they are used for many cancers and they want to promote themselves as having the latest and greatest technology to attract patients.

What types of imaging is most commonly reimbursed for treatment evaluation of metastatic breast cancer? What are the advantages and disadvantages of these types of imaging?
- CT and PET-CT pretty readily reimbursed. For other types of imaging, depends where the metastases are, e.g. if a woman has liver metastases, liver ultrasound would be readily reimbursed.
- The frequency of imaging is variable among payers.
- Patient anxiety: sometimes imaging is useful for reassuring the patient, but other times waiting for the results is very stressful for them.

Other guidelines used to determine choice of imaging besides NCCN?
- No. Even NCCN guidelines concluded there was not enough data to make suggestions about use of imaging for assessing response to therapy.
- NCCN guidelines heavily influenced by medical oncologists and other nonimagers.

Do accreditation programs influence the type of imaging chosen?
- For devices, the American College of Radiology (ACR) provides accreditation. Most centers maintain that accreditation, but it does not cover patient preparation, which is important.
- No accreditation for who reads PET-CT scans. Guidelines for minimum training to read scans exist but are not enforced.
- Even at major cancer centers, only 10 percent of PET-CTs done in a facility would be related to breast cancer so difficult for physicians at smaller centers to gain experience interpreting breast images.

What is the role of patient choice?
- Patient preferences usually push clinicians to do more tests and more expensive tests.
- For some physicians, it is easier to just order a test than take the time to argue about it with patients.
- Patients usually don't want to reduce their imaging. For example, once they have had PET-CT, they don't want to only CT.
- Patients often don't have tests explained to them, particularly the pros/cons, etc. Patients don't get enough information about the reasons for tests, what they mean, etc. because person interpreting scans rarely interacts with patient. They get much better explanations about treatment.
- Patients don't grasp the use of tests, their accuracy, interpretation, etc. Their research about their disease tends to focus on treatment.
- Patients often willing to take extreme risks to avoid the smallest chance of dying of breast cancer.

What factors related to imaging are most important to patients?
- Patients often do not realize several imaging modalities exist and they have options.
- Patients expect their tests to show them if treatment has been successful.
- Out-of-pocket expenses vary: patients who have good insurance coverage or Medicaid generally don't think about costs but patients with other types of insurance often have high copays and deductibles, requiring them to make decisions based on cost rather than what's best for their health.
- Many patients reach out-of-pocket maximum because of expense of treatment so during treatment are usually not concerned about out-of-pocket costs.
- Some patients have claustrophobia or reactions to contrast when receiving imaging, but in general the discomfort from imaging is much easier to tolerate than that from treatment.
- Imagers generally do not interact with patients. Communication is directed to the referring physicians but they don't necessarily communicate information about the images as well as the imager might.
- Patients discuss the inconvenience of tests, especially PET since it involves long idle periods of time needed to allow radiotracer circulation.
- A lot of imaging reassures patients (not a trivial issue) but provides no clinical benefit. Alternative ways to reassure patient might be less expensive and potentially have fewer risks.
- Patients discuss which imaging facilities are the most comfortable and offer them the most perks (e.g. warm blankets and herbal tea).
- Most patients do not consider the accuracy of imaging tests and usually do not research imaging on their own the way they research treatment options.

What emerging technologies can we expect in next 5 years or so?
- PET-MRI might become relevant for brain metastases because MR does a better job imaging the brain than CT.
- Emerging data show that if tests are done in a certain order, patient may avoid some (e.g. PET can obviate the need for a bone scan).
- Imaging with PET using 18F-fluoroestradiol (FES) as a tracer, may be available in 3-5 years.
- Patients would prefer blood test over imaging if it were accurate.
- So far for breast cancer, tumor markers and circulating malignant cells in blood samples are unreliable tests because breast cancer is such a heterogeneous disease. Hopefully in the next 10-15 years these tests will have improved so much that they will drastically curtail imaging.
- Quantitative assessment of treatment response using standard uptake value changes seen on FDG-PET after the first course of treatment would allow clinicians to know how the tumors are responding so they could adjust the doses of chemotherapies. Further research is needed before associations could be validated and reproducible.

What are some important research needs?
- New tracers for PET imaging
- Accurate tumor markers that could show whether patient is responding to treatment using a blood test instead of imaging.
- No studies of long-term outcomes. Do these technologies actually change outcomes, quality of life, or treatment selection? Current studies are generally single center, no clinical outcomes (especially long term). These could be embedded in therapeutic trials.
- Studies of communication with patients. The most knowledgeable person (the one interpreting the image) is often not available to patients for questions, especially in nonacademic settings.
- Studies that allow better understanding of tumor biology.
- Imaging technologies that identify smallest tumors possible to reduce breast cancer recurrence.
- Imaging that is more specific to each patient's type of cancer so a particular tumor could be characterized by the genetic or even proteomic level and then treated without damaging healthy tissue.
- Increased accuracy is needed to make a better treatment decisions.
- Use of imaging to evaluate side effects of treatment, e.g., women taking Herceptin (which can affect cardiac function) might have better outcomes if they received echocardiography during their treatment to determine whether their heart function was being affected. If it were, they could be put on medications that would minimize cardiac side effects. Most imaging currently focuses solely on the cancer and metastases, rather than other parts of the body that might be affected by toxic treatments.
- After baseline scan, how often should imaging be repeated?

What are barriers that inhibit research on imaging for treatment evaluation for metastatic breast cancer?
- New technologies are not used if there is no reimbursement for development.
- Regulatory barriers also exist. Time and cost for approval may deter development of product.