# Search Terms for Published Literature Review

Search # | Query | Number of Items Found
1 | exp Diagnostic Imaging | 1748368
2 | exp Breast Neoplasms/dh, dt, pc, rt, su, th [Diet Therapy, Drug Therapy, Prevention & Control, Radiotherapy, Surgery, Therapy] | 101694
3 | exp Neoplasm Metastasis | 158648
4 | secondary.fs. | 127910
5 | (stag$ adj3 (four or iv)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier] | 33298
6 | 3 or 4 or 5 | 286043
7 | exp Prognosis | 1108191
8 | exp “Outcome and Process Assessment (Health Care)” | 733807
9 | exp Mortality | 285802
10 | mo.fs. | 424456
11 | exp survival analysis | 192862
12 | 7 or 8 | 1173716
13 | 1 and 2 and 6 and 12 | 667
14 | exp *Breast Neoplasms/dh, dt, pc, rt, su, th | 65064
15 | 1 and 6 and 12 and 14 | 265
16 | exp “Outcome Assessment (Health Care)” | 710469
17 | 1 and 6 and 14 and 16 | 131
18 | ((treat$ or therap$ or interven$ or regimen$ or pharmacother$ or chemother$ or radiother$ or surger$ or surgic$) adj7 (effectiv$ or success$ or outcom$ or result$ or respons$ or reduc$ or remission$ or shrink$ or shrank or shrunk)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier] | 1753900
19 | 1 and 6 and 14 and 18 | 297
20 | 19 not 17 | 166
21 | Limit 20 to English language | 114
22 | ((assess$ or determin$ or establish$ or confirm$ or evaluat$ or monitor$ or discover$ or determin$ or learn$ or discern$) adj7 (effectiv$ or success$ or outcom$ or result$ or respons$ or reduc$ or remission$ or shrink$ or shrank or shrunk)).mp. | 963765
23 | 1 and 6 and 14 and 22 | 92
24 | Limit 23 to English language | 86
26 | 1 and 6 and 14 and 25 | 266
27 | 17 or 21 or 24 or 26 | 365
28 | Limit 27 to yr=”2003-Current” | 256
29 | Limit 28 to English language | 197
30 | Delete duplicates | 158