# Acronyms and Abbreviations

BC: breast cancer
CA15-3: cancer antigen 15-3
CA27-29: cancer antigen 27-29
CEA: carcinoembryonic antigen
CT: computed tomography
CTC: circulating tumor cell
ER+: estrogen receptor positive
FDA: U.S. Food and Drug Administration
FDG: fluorodeoxyglucose
FDG-PET: fluorodeoxyglucose positron emission tomography
FES: fluoroestradiol
F-FMISO: F-fluoromisonidazole
FLT: fluorothymidine
GL: gray literature
HER2: Human Epidermal Growth Factor Receptor-2
KI: Key Informant
MBC: metastatic breast cancer
MRI: magnetic resonance imaging
NA: not applicable
NR: not reported
NSD: no significant difference
PET: positron emission tomography
PET/CT: positron emission tomography/ computed tomography
PET/MRI: positron emission tomography/magnetic resonance imaging
PL: published literature
SD: standard deviation
SPECT: single-photon emission computed tomography
SUV: standardized uptake value