# Summary and Implications

## Important Issues Raised by the Technology (Guiding Question 4)

Key Informants raised several important issues regarding decision aids and their place in ACP.

As laid out in the findings, decision aids serve two broad functions in ACP: (1) to identify a proxy decisionmaker, and (2) to decide in advance on preferences for care in specific situations. Many Key Informants and some ACP Web sites promote a staged approach to ACP with the goals and outcomes varying by the individual's particular circumstances. Only those with advanced illness or at high risk of catastrophic health events are encouraged to seek specific information on their condition and options for life-sustaining treatments, and then encouraged to name a health care proxy decisionmaker and make sure that person is aware of care preferences. All others with less certain future health needs are simply encouraged to choose and document a health care proxy decisionmaker. Several Key Informants noted the difficulty of determining the information that will best serve people's needs unless the target audience is clearly defined, which is often easiest for disease-specific tools. A staged approach to ACP, based on how hypothetical the decision aid index question is and the level of uncertainty about the care choices to consider, would help guide the important education components, appropriate evaluation, and convergence with care planning.

Several Key Informants suggested that for people with serious or chronic critical illnesses, ACP functions best when integrated into overall care plans. Then, advanced care decisions can be discussed in the context of other care options and based on the options available in the chosen care setting, since services vary by location (e.g., nursing home versus hospital). Care decisions can imply a willingness to move to a more (or less) intensive environment (e.g., do not hospitalize instructions). Without explicit information about which services are available in various settings, patients may express preferences for or against therapies and for or against settings that turn out to be incompatible. Or they may express preference to decline certain therapies on a mistaken assumption that such an intervention can only be offered in the hospital.

For those with established conditions, ACP decisions need to be based, in part, on knowledge of prognosis. High-quality decision aids could inform patients about their prognosis and allow them to consider potential implications for health care decisions. Ideally, patients would be given information on the expected natural history of their condition(s) as well as the efficacy of various life-sustaining interventions to change the course or experience of illness, and potential harms. Clinical and administrative databases (i.e., Big Data) could provide current and continually updated information or prognosis and treatment efficacy in advanced illness. A challenge remains, however, when it comes to creating interactive or patient-specific tools that can help patients and clinicians estimate probabilities of intervention benefits in various circumstances near the end of life. Prognosis and planning is even more challenging for diseases with less certain trajectories (for example, heart disease or dementia versus metastatic cancer). This makes it hard for providers to know what to talk about when, and for designers of decision support materials to know what to include in a decision aid.

The need for such information in decision aids becomes clear in situations where patients and families anticipate future difficulties with maintenance of oral nutrition. The likelihood of such a problem varies across diseases, such as Alzheimer's, Parkinson's, strokes, ALS, and esophageal disorders. The benefits of medical nutrition, such as enteral feeding through a gastrostomy tube, also vary significantly depending on the cause of poor oral intake. Without data-rich decision aids, patients with early Alzheimer's might mistakenly believe there is therapeutic benefit from enteral feeding (none is found in multiple studies). Meanwhile, those with primary swallowing disorders might mistakenly extrapolate information from populations with dementia and underestimate the benefits of oral nutrition for their condition.

The way questions are posed by decision aids can affect responses. Several Key Informants noted discomfort with some ACP video images of people with advanced illness. They noted that the images could be alarming to people of generally good health who are far from experiencing such diminished health states, and thus bias viewers towards less care than they may otherwise have chosen. Providing accurate information and frames that portray a realistic range of health state experiences is challenging, and a “good balance” may very well be in the eye of the beholder. Other Key Informants found video vignettes particularly important for engaging people in the decisionmaking process for ACP, helping them envision possible future health states they may have otherwise avoided. However, the use of heuristics for decisionmaking tends to increase as decisional complexity increases, such as when a person's emotional intensity state is high.44

Key Informants suggested taking the “A” out of ACP by making ACP an ongoing process rather than a one-time decision to be documented. Certainly, decisions need to be revisited as a patient's condition deteriorates. The Gold Standards Framework Tool “Thinking Ahead – GSF Advance Care Planning Discussion” guide is one example of a tool intended as a dynamic document to be adapted and reviewed as needed. However, other Key Informants stressed that the urgent need to have people complete at least one ACP should take precedence over creating decision aids to support dynamic ACPs.

Several Key Informants noted that decision aids need to be tolerant of the many philosophical perspectives that people may bring to the process. In a country as diverse as the United States, decision aids should be culturally and spiritually sensitive to traditions and supportive of nuanced decisions. Decision aids should be flexible to the process rather than focused solely on the outcome.

Key Informants expressed concern over the use of computer-based decision aids and ACP documentation tools due to potential access problems should there be exclusive or over-reliance of Web-based tools. This concern also applied to decision aids and tools not free and easily available to the public. Certain patient populations without easy access to computer resources are disadvantaged. One way to provide ACP decision aids to vulnerable populations would be through ACP bringing the decision aid materials or resources to the patients.

Key Informants differed on the role of specialized facilitators and who would best fulfill such a role. Differences could concern the specific professional training (e.g., social workers and nurses versus clergy versus physicians versus lawyers) or might reflect specialized training in ACP facilitation regardless of discipline. The latter approach highlights the skills the facilitator brings to the encounter rather than the role. Yet, the greater the demand for special status, the greater the tendency for problems with access issues due to increased costs. As a prime skill regardless of who fills the role, Key Informants noted the ability to respect the decision made, whether or not the facilitator agrees with it.

Although providers are often the automatic default facilitators, several Key Informants noted that physicians are often the most challenged to facilitate conversations a difficulty they attributed to various causes, from personal difficulty with talking about dying and end-of-life decisions when their training and motivation is toward curing and prolonging life to more traditional concerns regarding patriarchal attitudes. To this, we add the practical barriers that hinder physicians from engaging in ACP conversations, such as time constraints, financial disincentives, and the absence of effective strategies for promoting ACP conversations.

Although most ACP tools include choice of proxy decisionmaker, Key Informants noted a lack of decision aids designed to help people choose a proxy well. However, a couple of attempts have been made. For example, Caring Connections provides some links on their Web page, but does not directly take up the task. Key Informants further noted that in-depth conversations between people and their proxies are needed to establish clarity about personal values and outcome preferences. These conversations give the proxy a sense of confidence for representing the patient when end-of-life decisions must finally be made. One Key Informant noted that voice recordings of the patient's preferences and values can be a powerful way to make the patient's wishes “real” during the difficult times.

Ultimately, decision aids provide a structure that allows people to deeply consider and document their preferences and support important relationships. A well-considered and communicated preference helps doctors feel assured and comfortable about the ethics of providing or withholding treatments that affect survival. Effective decision aids help provide closure to family and loved ones who will live with the consequences.