# References

1 Kaldjian LC, Curtis AE, Shinkunas LA, et al. Goals of care toward the end of life: a structured literature review. American Journal of Hospice & Palliative Medicine. 2008 Dec-2009 Jan. 25(6):501-11. [pmid: 19106284].
2 Heyland DK, Dodek P, Rocker G, et al. What matters most in end-of-life care: perceptions of seriously ill patients and their family members. Canadian Medical Association Journal. 2006;174(5):627-33. [pmid: 16505458].
3 Emmanuel L, Scandrett KG. Decisions at the end of life: have we come of age?. BMC Medicine. 2010;8:57. [pmid: 20932275].
4 Daaleman TP, VandeCreek L. Placing religion and spirituality in end-of-life care. JAMA. 2000;284(19):2514-7. [pmid: 11074785].
5 Balboni TA, Balboni M, Enzinger AC, et al. Provision of spiritual support to patients with advanced cancer by religious communities and associations with medical care at the end of life. JAMA Internal Medicine. 2013;173(12):1109-17. [pmid: 23649656].
6 Wilkinson A, Wenger N, Shugarman LR. Literature review on advance directives. 2007.
7 Witherspoon GS. What I learned from Schiavo. Hastings Center Report. 2007;37:17-20. [pmid: 18179100].
8 O'Connor AM, Stacey D, Entwistle V, et al. Decision aids for people facing health treatment or screening decisions (Cochrane Review). Chichester, UK. 2004.
9 Elwyn G, O'Connor AM, Bennett C, et al. Assessing the quality of decision support technologies using the international patient decision aid standards instrument (IPDASi). PLoS One. 2009;4(3):e4705. [pmid: 19259269].
10 Dolan P. Addressing misconception in valuing health. Expert Review of Pharmacoeconomics & Outcomes Research. 2013;13(1):2-4. [pmid: 23402439].
11 Ubel PA, Loewenstein G, Schwarz N, et al. Misimagining the unimaginable: the disability paradox and health care decision making. Health Psychology. 2005;24(4 Suppl):S57-62. [pmid: 16045420].
12 Sackett DL, Torrance GW. The utility of different health states as perceived by the general public. Journal of Chronic Diseases. 1978;31(11):697-704. [pmid: 730825].
13 Kind P, Dolan P. The effect of past and present illness experience of the valuations of health states. Medical Care. 1995;33(4 Suppl):AS255-63. [pmid: 7723454].
14 Stacey D, Legare F, Col N, et al. Decision aids for people facing health treatment or screening decisions. 2014.
15 Advance Care Planning, Preferences for Care at the End of Life: Research in Action. Rockville, MD. March. 2003. www.ahrq.gov/research/findings/factsheets/aging/endliferia/index.html.
16 Virmani J, Schneiderman LJ, Kaplan RM. Relationship of advance directives to physician-patient communication. Archives of Internal Medicine. Apr. 25. 1994;154(8):909-13. [pmid: 8154954].
17 Teno J, Lynn J, Wenger N, et al. Advance directives for seriously ill hospitalized patients: effectiveness with the patient self-determination act and the SUPPORT intervention. Journal of the American Geriatrics Society. 1997;45(4):500-7. [pmid: 9100721].
18 Teno J, Licks S, Lynn J, et al. Do advance directives provide instructions that direct care?. Journal of the American Geriatrics Society. 1997;45:508-12. [pmid: 9100722].
19 Bradley EH, Rizzo JA. Public information and private search: evaluating the Patient Self-Determination Act. Journal of Health Politics, Policy, and Law. 1999;24(2):239-73. [pmid: 10321357].
20 Coppola KH, Ditto PH, Danks JH, et al. Accuracy of primary care and hospital-based physicians' predictions of elderly outpatients' treatment preferences with and without advance directives. Archives of Internal Medicine. 2001;161:431-40. [pmid: 11176769].
21 Montori VM, Gafni A, Charles C. A shared treatment decision-making approach between patients with chronic conditions and their clinicians: The case of diabetes. Health Expectations. 2006;9:25-36. [pmid: 16436159].
22 Charles C, Gafni A, Whelan T. Shared decision-making in the medical encounter: What does it mean? (Or it takes at least two to tango). Social Science and Medicine. 1997;44:681-692. [pmid: 9032835].
23 Halliday S, Witteck L. Decision-making at the end-of-life and the incompetent patient: a comparative approach. Medicine & Law. 2003;22(3):533-42. [pmid: 14626885].
24 Covinsky KE, Goldman L, Cook EF, et al. The impact of serious illness on patients' families. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. JAMA. Dec. 21. 1994;272(23):1839-44. [pmid: 7990218].
25 Allen RS, Allen JY, Hilgeman MM, et al. End-of-life decision-making, decisional conflict, and enhanced information: race effects. Journal of the American Geriatrics Society. Oct. 2008;56(10):1904-9. [pmid: 18775035].
26 Deep KS, Hunter A, Murphy K, et al. “It helps me see with my heart”: how video informs patients' rationale for decisions about future care in advanced dementia. Patient Education & Counseling. Nov. 2010;81(2):229-34. [pmid: 20194000].
27 Ditto PH, Danks JH, Smucker WD, et al. Advance directives as acts of communication: a randomized controlled trial. Archives of Internal Medicine. Feb. 12. 2001;161(3):421-30. [pmid: 11176768].
28 Green MJ, Levi BH. Development of an interactive computer program for advance care planning. Health Expectations. Mar. 2009;12(1):60-9. [pmid: 18823445].
29 Green MJ, Levi BH. Teaching advance care planning to medical students with a computer-based decision aid. Journal of Cancer Education. Mar. 2011;26(1):82-91. [pmid: 20632222].
30 Hossler C, Levi BH, Simmons Z, et al. Advance care planning for patients with ALS: feasibility of an interactive computer program. Amyotrophic Lateral Sclerosis. May. 2011;12(3):172-7. [pmid: 20812887].
31 Levi BH, Heverley SR, Green MJ. Accuracy of a decision aid for advance care planning: simulated end-of-life decision making. Journal of Clinical Ethics. 2011;22(3):223-38. [pmid: 22167985].
32 Murphy CP, Sweeney MA, Chiriboga D. An educational intervention for advance directives. Journal of Professional Nursing. Jan-Feb. 2000;16(1):21-30. [pmid: 10659516].
33 Smith TJ, Dow LA, Virago EA, et al. A pilot trial of decision aids to give truthful prognostic and treatment information to chemotherapy patients with advanced cancer. The Journal of Supportive Oncology. Mar-Apr. 2011;9(2):79-86. [pmid: 21542415].
34 Song MK, Kirchhoff KT, Douglas J, et al. A randomized, controlled trial to improve advance care planning among patients undergoing cardiac surgery. Medical Care. Oct. 2005;43(10):1049-53. [pmid: 16166875].
35 Volandes AE, Ferguson LA, Davis AD, et al. Assessing end-of-life preferences for advanced dementia in rural patients using an educational video: a randomized controlled trial. Journal of Palliative Medicine. Feb. 2011;14(2):169-77. [pmid: 21254815].
36 Volandes AE, Levin TT, Slovin S, et al. Augmenting advance care planning in poor prognosis cancer with a video decision aid: a preintervention-postintervention study. Cancer. Sep. 1. 2012;118(17):4331-8. [pmid: 22252775].
37 Volandes AE, Mitchell SL, Gillick MR, et al. Using video images to improve the accuracy of surrogate decision-making: a randomized controlled trial. Journal of the American Medical Directors Association. Oct. 2009;10(8):575-80. [pmid: 19808156].
38 Volandes AE, Paasche-Orlow MK, Barry MJ, et al. Video decision support tool for advance care planning in dementia: randomised controlled trial. BMJ. 2009;338:b2159. [pmid: 19477893].
39 Stocking CB, Hougham GW, Danner DD, et al. Empirical assessment of a research advance directive for persons with dementia and their proxies. Journal of the American Geriatrics Society. Oct. 2007;55(10):1609-12. [pmid: 17714461].
40 Bravo G, Arcand M, Blanchette D, et al. Promoting advance planning for health care and research among older adults: a randomized controlled trial. BMC Medical Ethics. 2012;13:1. [pmid: 22221980].
41 Matlock D, Keech T, McKenzie M, et al. Feasibility and acceptabilityof a decision aid designed for people facing advanced or terminal illness: a pilot randomized trial. Health Expectations. 2011. [pmid: 22032553].
42 Vogel RI, Petzel SV, Cragg J, et al. Development and pilot of an advance care planning website for women with ovarian cancer: a randomized controlled trial. Gynecol Oncol. Nov. 2013;131(2):430-6. [pmid: 23988413].
43 Song MK, Sereika SM. An evaluation of the Decisional Conflict Scale for measuring the quality of end-of-life decision making. Patient Education & Counseling. Jun. 2006;61(3):397-404. [pmid: 15970420].
44 Arana J, Leon C, Hanemann M. Emotions and decision rules in discrete choice experiments for valuing health care programmes for the elderly. Journal of Health Economics. May. 2008;27(3):753-69. [pmid: 18241944].