# Next Steps

Future directions for efforts to improve ACP decision aids fall into three categories.

1. Research is needed:
  - Well-designed, validated tools that are easily accessible, readable, understandable, and appropriate to patients across various settings working with various facilitators. Some progress has been made, but much remains to be done. A broad array of tools may be needed to meet the needs of the broad array of professionals, in different settings, and at various stages of the Figure 1 map.
  - Comparing various decision aids, including patient and provider satisfaction, impact on preferences stated, and efficiency of the ACP processes. These studies might include attention to who facilitates decisions and how.
  - Better ways of presenting risk information to patients, more individualized predictive models for life expectancy that can be incorporated into ACP decision aids, and understanding if the risk information improved patient decisionmaking. Alternatively, tools could also be developed to better help patients cope with or adapt to uncertainty as an inherent part of ACP and life course.
  - Effectiveness of various end-of-life interventions in different clinical populations. This information would improve the educational components of ACP decision aids.
  - Ways to design decision aids that enable patients to work backwards from their preferred site of care to then decide which therapies they might accept in that setting (because location of care is sometimes a dominant preference in ACP).
  - Ways to evaluate decision aids for the context within which they are intended to be used, because professionals supporting ACP may include clinicians, lawyers, social workers, and clergy (or none).
  All of the research next steps would be furthered by agreement on a core set of outcomes to assess the effectiveness of the decision aids. Table 7 provides a possible core set derived from the IPDAS criteria and outcomes used in the empirical literature. The listed outcomes diverge from the IPDAS set with outcomes related to the surrogate decisionmaker's role in ACP. Serious consideration should also be given to what “harms” should be consistently collected in ACP decision aid research as well.
2. Training of current or future facilitators of ACP (health professionals, attorneys, clergy, social workers) is needed regarding:
  - Shared decisionmaking, using decision aids.
  - Use of decision aids, to reduce variation in the process of ACP.
  - Value of decision aids, to improve clarity of verbal and written communication.
  - More understanding of how the background of the decision facilitator affects the decision processes.
3. Use of social media and other technologies provide further opportunities to improve decision aid development.
  - Create decision aids that provide personal narratives based on patient experiences in various health conditions and after receiving life prolonging therapies. Several of the decision aid resources presented here have started this process. More could be accomplished using social media to democratize the process of sharing and collecting patient experiences.
  - Social media and other big data sources may also allow access to more fine-grained individualized information to help improve not only prognostic abilities, but also to illuminate what choices people have made and the resulting course. People like to know how other people have chosen and behaved.

Table 7 Potential outcome measure by stage

Outcome | Stage of Health / Illness
| Healthy | Potentially Life Threatening Illness | Life Threatening Illness or Event | Hospice or Frail Elderly
Extending autonomy | | | X | X
Wishes honored | | ? | X | X
Improved decisionmaking | X | X | X | X
Improved communication | X | X | X | X
Patient/provider concordance | X | X | X | X
Patient/surrogate concordance | X | X | X | X
Surrogate understanding of patient's wishes | X | X | X | X
Surrogate comfort | X | X | X | X
Satisfaction | X | X | X | X
Helpfulness | X | X | X | X
Decisional conflict | X | X | X | X
Sense of control | X | X | X | X
Improved emotional state/hope/reduction of anxiety | | X | X | X
Knowledge | X | X | X | X
Care intensity consistent with preferences | X | X | X | X