# Methods

Technical Briefs are products of the Effective Health Care Program on important but underdeveloped topics in terms of the availability of high-quality studies. Technical Briefs provide an overview of key issues and describe available evidence. Technical Briefs do not provide synthesized evidence or grade or rate the strength of the evidence of the literature. Data presented in a Technical Brief cannot be used to develop standards or guidelines, to endorse one practice over another, or to inform policy or payment decisions, but are useful in providing direction on next steps necessary to move the topic in the direction of the development of an evidence base from which to accomplish these goals.

We integrated information from Key Informants and a literature review. In general, responses to Guiding Questions 1, 2, and 4 relied on information from Key Informants as well as gray literature and published information about decision aids and the context within which they are used. Responses to Guiding Question 3 are based on peer-reviewed, published studies that examined outcomes after the use of decision aids.

## Discussion With Key Informants

We identified relevant Key Informants with the goals of efficient data collection and balanced viewpoints. We included practicing clinicians and attorneys involved in ACP, experts in medical law and medical ethics, consumer advocates, and decision aid researchers and developers. We located Key Informants from frequently listed and cited authors of relevant literature, Internet searches for possible candidates of relevant viewpoints, and nominations by other Key Informants. When we could not identify an individual to represent a specific organization, we invited the organization to nominate an individual.

We conducted semi-structured interviews with Key Informants via telephone during November 2013. Interview guides for each group of Key Informants were developed in advance. The guides are presented in Appendix A.

## Gray Literature Search

We conducted a gray literature search of Federal and State government Web sites, the Ottawa Hospital Research Institute's Decision Aid Library Inventory, professional organizations, and leads from Key Informants for current decision aids available to the public and in use. Appendix C provides a list of organization Web sites searched. Resources from Web sites that provide downloadable forms for advance directive or POLST completion were excluded if they did not provide additional education or help clarify values. We also excluded resources that provided education only, without prompting action on the part of the user (e.g., ALS Association: Respiratory Decisions Guide, PBS: End of Life Dilemmas Video, Choosing Wisely: Feeding Tubes for People with Alzheimer's Disease Fact Sheet, American Health Lawyer Association: Loving Conversations Videos, Sutter VNA & Hospice: Advance Directive Intervention List).

We also searched the Internet with Google to find information on decision aids for ACP as well as on issues and controversies regarding their use. We surveyed enrolling and ongoing clinical trials though the ClinicalTrials.gov, HSRProj, and NIH RePORTER databases, and the PCORI Web site. We also searched LexisNexis for current discussions of legal/ethical considerations and controversies.

## Published Literature Search

We searched MEDLINE^®^ via OVID, the Cochrane Library, PsychINFO, and CINAHL databases through May, 2014. Exact search strategies were developed in consultation with the EPC librarian. We developed an a priori search strategy based on relevant medical subject headings (MeSH) terms and text words. The search string is provided in Appendix B. We also searched the databases using as key words the decision aids located in the gray literature.

We screened the resulting literature for relevant published articles of empirical research. For Guiding Question 3, we searched for eligible studies that examined the use of decision aids for advance care planning. We included intervention studies published in English of any sample size and any design (randomized controlled trial, controlled clinical trial, uncontrolled observational trial, and case reports and series). We excluded studies that focus on implementation science questions, including studies where the effect of a facilitator could not be separated from the effects of the decision aid. Further inclusion/exclusion criteria are provided in Table 2.

Table 2 Inclusion/exclusion criteria by PICOTS

Element | Included | Excluded
Population | Any adult potential patient, whether general or identified by disease | Pediatric patients, non-U.S. populations. Decisions must be for future care, not current care, and under consideration by the individual, not the proxy.
Interventions | Decision aids for future health states that include a behavioral prompt | - Religious or other edicts that specify what decision a patient should make (e.g., “artificial nutrition must be accepted” or “blood transfusions may not be accepted”).; - An attorney's standard paragraph about preferences inserted into a health care directive that does not provide information about risks, benefits, or alternatives.; - A simple form that names a health care proxy (without providing a list of powers to choose from that would be afforded to the proxy).; - Health care providers' verbal recommendations.; - Educational materials and research publications intended for health care professionals to help them give verbal recommendations to patients.; - Educational materials that only promote the process of advance care planning, without providing information to help individuals make the decisions that are part of ACP.; - Statutes, government policies, and health care institutional policy and procedure that describe and promote ACP or specify decision aids that must be used.; - Advance planning for psychiatric care; decisions about treatment for a disease, not end of life decisions.; Studies where the effects of the ACP facilitator could not be separated from the effects of the decision aid.
Comparators | No aid, “traditional care,” education-only material
Outcomes | Decision agreement, confidence, patient satisfaction, knowledge, comfort, uptake. May be either patient or family/caregiver | Implementation or process measures
Timing | Decisions made for future health states | Decision of current, not future or hypothetical, end-of-life decisions for current health states
Settings | Decision aids used for health care or legal settings, whether in the presence of an attorney or do-it-yourself Web sites

## Data Organization and Presentation

We abstracted data from the published literature using standardized data abstraction tables. One reviewer collected the data and assessed the evidence against the inclusion and exclusion criteria. We did not abstract actual results from the studies.

Data from the published literature were integrated with information from the gray literature and discussions with Key Informants. Responses to Guiding Questions 1 and 2 were formed with information from published narrative reviews, information in the gray literature, and Key Informant discussions. Responses to Guiding Question 3 were based primarily on peer-reviewed, published literature and may be combined with information gleaned from the gray literature (e.g., information from ongoing studies). Responses to Guiding Question 4 were informed by Key Informant discussions along with information used to address Guiding Questions 1–3.

The data are presented in narrative form (Guiding Questions 1, 2, and 4) and in evidence tables. We summarized the evidence into summary tables/plots by decision aid and its use. The tables are organized to provide descriptive details of identified decision aids and their conformance to decision aids criteria. For the criteria, we used the IPDAS instrument.9