# Guiding Questions

The questions we formulated to guide the Technical Brief process are listed below.

1. What decision aids for ACP have been proposed or used in practice?
  a. What are the characteristics of the decision aid, such as the goal, mode of delivery, and settings in which it is used?
  b. How well do the decision aids meet decision aid criteria?
2. In what contexts are decision aids for ACP currently used, and what are the limitations to their use?
  a. Who generally facilitates the ACP decision process in which the decision aid is used?
  b. How are the decisions generated by the decision aid documented?
  c. How are the decision aid and/or its documentation transferred/communicated to health care settings where the health care activities take place?
  d. What are the implications of the combination of the health state of the person completing the decision aid, the setting in which the decision aid is completed, and whether the decisions are hypothetical or concrete?
  e. What is the legal environment and requirements for ACP for which the decision aids are used?
3. What is the current evidence on decision aids for ACP?
  a. What decision aids have been studied for effectiveness?
  b. What are the inclusion and exclusion criteria of people in studies of the effectiveness of decision aids?
  c. What settings were examined?
  d. What outcomes were examined?
  e. Were harms or adverse effects collected in the studies; what were they?
  f. What comparators were used to examine benefits and harms?
4. What are the important issues raised by decision aids for advance care planning and how they are used?
  a. What are the ethical considerations regarding using decision aids for ACP?
  b. How are people guided in choosing health care proxies?
  c. What are the implications of legal versus health care settings for ACP; do the decision aids adequately address the related concerns?
  d. What are possible areas of future research?