# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Jean Kutner, M.D., M.S.P.H.
  Professor, University of Colorado School of Medicine
  President, American Academy of Hospice and Palliative Medicine
  Denver, CO
- Jean Kutner, M.D., M.S.P.H.
  Professor, University of Colorado School of Medicine
  President, American Academy of Hospice and Palliative Medicine
  Denver, CO
- Benjamin Levi, M.D., Ph.D., FAAP
  Advanced care planning decision aids researcher
  Penn State College of Medicine
  Hershey, PA
- Daniel Matlock, M.D., M.P.H.
  Advanced care planning decision aids researcher
  Assistant Professor of Medicine, Division of General Internal Medicine
  University of Colorado School of Medicine
  Aurora, CO
- Charles Sabatino, J.D.
  Borchard Foundation Center on Law & Aging
  Washington, DC