# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Jon Broyles
  Coalition to Transform Advanced Care (C-TAC)
  Washington, DC
- David English, J.D.
  American Bar Association Commission on Law and Aging
  University of Missouri School of Law
  Columbia, MO
- Floyd J. Fowler Jr., Ph.D.
  Informed Medical Decisions Foundation
  Boston, MA
- Joanne Lynn, M.D., M.A., M.S.
  Center for Elder Care and Advanced Illness
  Altarum Institute
  Washington, DC
- Robert Pearlman, M.D., M.P.H.
  Washington VA National Center for Ethics in Health Care
  Seattle, WA
- Thaddeus Pope, Ph.D.
  Hamline University School of Law
  St. Paul, MN
- Peg Sandeen, Ph.D., M.S.W.
  Death with Dignity
  Portland, OR