# Acknowledgments

We thank William Lawrence and Tim Carey, whose comments only improved the report. Thanks also to Jeannine Ouellette and Marilyn Eells for the exceptional editing support.