# Findings

## Description of Existing Decision Aids for ACP

### Existing Decision Aid Tools (Guiding Question 1)

The ideal ACP process is thought to occur through discussions between patients and their health care providers as part of a shared care planning process. In shared clinical decisionmaking, patients and clinicians use evidence-based knowledge, weigh options against treatment goals, and consensually arrive at a clinically prudent decision concordant with patient preferences.21,22 Pragmatically, decision aids aim to increase patient participation and/or empowerment in decisionmaking. Although ACP is within the bounds of clinical decisionmaking, it differs from many well-studied decision processes for medical procedures (e.g., surgical or nonsurgical options for cancer) because people can complete decisionmaking with no health care provider involvement, using do-it-yourself decision aids readily available to the public. These decision aids tend to target people with only general risks of life-threatening conditions, for whom ACP may involve considering a wide range of possible future scenarios, eliciting preferred goals of care, or choosing a proxy decisionmaker.

General decision aids for ACP are often used in conjunction with tools to document the decisions, whether treatment-based, end-of-life based, or values-based. Preferences for health care can be documented in an advance directive, also known as a living will, and stored at Web sites such as MyDirectives.com. One or more proxy health care decisionmakers and their powers can be documented in a durable power of attorney for health care or as part of a more comprehensive advance directive. Health care providers can record ACP results (whether from oral discussions or in an advance directive) into health care records, a specific order (e.g., Do Not Resuscitate), or into a template most commonly called a Physician Order for Life Sustaining Treatment (POLST, found at www.polst.org). This option has the advantage of serving as standing orders.

ACP, particularly among healthy adults, occurs largely outside of clinical settings, where it is often facilitated by estate or family law attorneys or social workers rather than medical providers. Because non-medical facilitators may have limited ability to discuss health care scenarios or the success rates and consequences of life sustaining interventions, high quality decision aids would be valuable in these situations.

ACP decision aids can also address questions regarding where patients wish to die, such as in their own homes, at hospice facilities, or in skilled nursing or hospital settings. Choice of setting can have implications for available interventions. Some interventions are available only in a hospital setting (e.g., surgery), while some must be initiated in the hospital but can be managed long term at home or in a nursing facility (e.g., ventilator care). Intravenous therapies can be initiated and maintained in various settings.

Decision aids for ACP for patients with specific disease conditions can walk the undefined line between advance care planning and care planning. For people with predictable progressive disease (such as amyotrophic lateral sclerosis), chronic critical illness, or frailty, a structured approach to decisions in ACP often requires information regarding a person's prognosis. A patient may need to review data on life-expectancy and likelihood of pain or loss of function in order to decide for or against future life-prolonging therapies. In addition, well-informed ACP often requires intervention-specific information such as typical response and added lengths of survival. This poses significant challenges for those creating decision aids for ACP, as prognoses are often uncertain for individual patients and information on benefits of end-of-life treatments are rarely available for specific populations that match a patient's circumstances.

Tables 3a and 3b describe generally available tools for ACP. These tools were identified through the gray literature search and by Key Informants. The list is not exhaustive. It captures the more commonly known decision aids, or those relatively easy to find online via common search engines. These tools vary in the degree to which they meet the three criteria of our working ACP decision aids definition, based on the IPDAS instrument criteria:8,9 an education component, a structured approach to thinking about the choices a patient faces, and a way for those choices to be communicated. Tools in both tables are indexed by decision and degree to which the tool meets the three decision aid criteria.

Table 3a Examples of general ACP tools publicly available on the World Wide Web

Organization/Name of Tool | Topics Addressed by Tool | | | | | | | | Developer's Description | DA Criteria | | | URL
Organization/Name of Tool | Living Will or AD | Health Agent | Life Sustaining Treatments-Multiple | States Worse than Death | Organ and Tissue Donation | Conversation Prompts | Treatment Location | Comfort Care Value Identification | Developer's Description | Provides Education | Structured Approach | Decision Communication | URL
ADVault Inc./MyDirectives | X | X | X | | X | X | X | X | MyDirectives is the first completely online advance directive that is secure, legal, easy to understand, and free. MyDirectives is also the first advance care platform to receive “meaningful use” certification from HHS so that hospitals may be eligible for incentive payments from Medicare and Medicaid under the American Recovery and Reinvestment Act when using this technology | M | M | H | www.mydirectives.com/?MyD
Aging with Dignity / The Five Wishes | X | X | X | | | | | X | The Five Wishes document helps individuals express care options and preferences. The advance directive meets the legal requirements in most states and is available in 20 languages for a nominal fee. | L | L | M | www.agingwithdignity.org/five-wishes.php
American Bar Association / Consumer's Toolkit for Health Care Advance Planning | | X | X | X | X | X | | X | The tool kit does not create a formal advance directive for you. Instead, it helps you do the much harder job of discovering, clarifying, and communicating what is important to you in the face of serious illness. | L | M | M | www.americanbar.org/groups/law_aging/resources/consumer_s_toolkit_for_health_care_advance_planning.html
Caring Connections: National Hospice and Palliative Care Organization / End-of-Life Decisions | X | X | X | | | | | | This booklet addresses issues that matter to us all, because we will all face the end of life. Advance directives are valuable tools to help us communicate our wishes about our future medical care. | M | L | L | www.caringinfo.org/files/public/brochures/End-of-Life_Decisions.pdf
Center for Practical Bioethics/Caring Conversations | X | X | X | | | | | X | Caring Conversations equips you with the tools you will need to communicate your wishes when you can no longer speak for yourself and advocate on your own behalf. The workbook includes a Durable Power of Attorney for Healthcare Decisions form and a Healthcare Treatment Directive form. | L | M | M | www.cpbmembers.org/documents/Caring-Conversations.pdf
Coalition for Compassionate Care of California/ Advance Care Planning Conversation Guide | | | | | | X | | | The ACP conversation guide provides suggestions on how to raise the issue, responses to concerns your loved one might express, and questions to ask. | L | L | L | http://coalitionccc.org/wp-content/uploads/2014/01/Advance-Care-Planning-Conversation-Guide1.pdf
Conversation Project, Institute for Healthcare Improvement/Conversation Starter Kit and How to Talk to Your Doctor | | | | | | X | | X | The Conversation Project is dedicated to helping people talk about their wishes for end-of-life care with family members and physicians. | M | M | M | http://theconversationproject.org/wp-content/uploads/2013/01/TCP-StarterKit.pdf
Engage with Grace/Engage with Grace: The One Slide Project | | | | | | X | | | The One Slide Project was designed with one simple goal: to help get the conversation about end of life experience started. The idea is simple: Create a tool to help get people talking. One Slide, with just five questions on it. Five questions designed to help get us talking with each other, with our loved ones, about our preferences. | L | L | L | www.engagewithgrace.org/
Georgia Health Decisions/CRITICAL Conditions Planning Guide | X | X | | | X | | | X | The CRITICAL Conditions Planning Guide walks you through advance care planning, beginning with meaningful conversations among your family members and resulting in the legal documentation of your preferences. | L | M | M | www.critical-conditions.org/preview.html
Lancashire and South Cumbria Cancer Services Network/Preferred Priorities for Care (PPC) | | X | | | | | X | X | The PPC document is recommended to help identify patient preferences for end-of-life care and prevent unwanted hospital admissions at the end of life. | L | L | M | www.dyingmatters.org/sites/default/files/user/images/PPC%20final%20document.pdf
The Regents of the University of California/ PREPARE | X | X | | | | X | | X | PREPARE is an interactive Web site serving as a resource for families navigating medical decisionmaking. PREPARE is a program that can help you: make medical decisions for yourself and others, talk with your doctors, get the medical care that is right for you. | M | H | H | https://www.prepareforyourcare.org/

L=low, M=medium, H=high

Table 3b Examples of ACP tools for those with serious or advanced illness publicly available on the World Wide Web

Organization/Name of Tool | Topics Addressed by Tools | | | | | | | | | | Developer's Description | DA Criteria | | | URL
Organization/Name of Tool | Living Will or AD | Health Agent | Life Sustaining Treatment | Life Support & CPR | Kidney Dialysis | Pain | Artificial Nutrition & Hydration | Conversation Prompts | Treatment Location | Comfort Care Value Identification | Developer's Description | Provides Education | Structured Approach | Decision Communication | URL
American College of Physicians/PEACE Series | | X | | | | X | | X | | X | The Consensus Panel project convened a second group of experts to develop patient education materials and Web content on end-of-life care for patients with serious or advanced illness. ACP's End-of-Life Care PEACE Series patient education brochures are available in print or to view online. | M | L | L | www.acponline.org/patients_families/end_of_life_issues/peace/
Healthwise/Should I have artificial hydration and nutrition | | | | | | | X | | | X | This decision aid is for patients considering artificial hydration and nutrition if or when they are no longer able to take food or fluids by mouth. | H | H | M | https://print.healthwise.net/kaiser/kpisg/Print/PrintTableOfContents.aspx?token=kpisg&localization=en-us&version=&docid=tu4431
National Cancer Institute at the NIH/Questions to Ask Your Doctor About Advanced Cancer | | | | | | | | X | | | If you learn that you have advanced cancer, you may have choices to make about care and next steps. When you meet with your doctor, consider asking some of the following questions. | L | L | L | www.cancer.gov/cancertopics/cancerlibrary/questions/advanced-cancer
Healthwise/Should I stop kidney dialysis? | | | | | X | | | | | X | This decision aid helps patients with kidney failure who have been undergoing dialysis, and for whom kidney transplantation is not possible, decide whether to continue kidney dialysis, which will allow you to live longer or stop kidney dialysis, which will allow death to occur naturally. | H | H | M | https://print.healthwise.net/kaiser/kpisg/Print/PrintTableOfContents.aspx?token=kpisg&localization=en-us&version=&docid=tu6095
Healthwise/Should I receive CPR and life support | | | | X | | | | | | X | This decision aid helps patients with serious or advanced illness decide whether or not to receive CPR and be put on a ventilator if heart or breathing stops. | H | H | M | https://print.healthwise.net/kaiser/kpisg/Print/PrintTableOfContents.aspx?token=kpisg&localization=en-us&version=&docid=tu2951
Healthwise/Should I stop treatment that prolongs my life? | | | X | | | | | | | X | This decision aid helps patients with serious or advanced illness decide whether to stop treatment that prolongs life and instead receive only hospice care, or to continue treatment that prolongs life. | H | H | M | https://print.healthwise.net/kaiser/kpisg/Print/PrintTableOfContents.aspx?token=kpisg&localization=en-us&version=&docid=tu1430
Informed Medical Decisions Foundation/Looking Ahead: Choices for Medical Care When You're Seriously Ill | X | X | X | | | | | | | X | This program is for people with a serious illness that is or may become life threatening. This program is also for family members and caregivers. The program describes different types of medical care, such as palliative care and hospice care, and reviews various types of advance directives. | M | L | M | During report preparation this decision aid became proprietary under a different organization. See www.healthdialog.com/Utility/News/PressRelease/14-01-17/Health_Dialog_and_the_Informed_Medical_Decisions_Foundation_Restructure_Longstanding_Relationship.aspx&num;
Ottawa Patient Decision Aid Research Group/When you need extra care, should you receive at home or in a facility? | | | | | | | | | X | | This decision aid helps patients with serious or advanced illness decide whether they would like to receive care at home or in a facility | H | H | H | http://decisionaid.ohri.ca/docs/das/Place_of_Care.pdf

L=low, M=medium, H=high

Table 3a describes 10 general ACP decision tools for healthy older adults with an undetermined illness trajectory. The most popular ACP topics covered by tools in Table 3a include: designating a health agent or proxy decisionmaker (7/10), value clarification and desire for comfort care at the end of life (7/10), information on living wills or advance directives (5/10), conversation prompts for talking to loved ones or physicians about wishes (5/10), and general preferences for various life sustaining treatments (4/10). Other topics considered included: organ and tissue donation (2/10), identification of states worse than death (1/10), and preference for treatment location (1/10). Many of the general tools targeted at healthy older adults address multiple ACP topics (mode, four topics per tool). The breadth of the general tools is great, but the depth is compromised. This is evidenced in the degree to which the tools meet decision aid criteria. Most tools provide low or medium levels of education and decisional structure. They provide communication of decisions because they are often attached to an advanced directive or living will, or prompt completing one.

In contrast, Table 3b includes eight tools for individuals with a life limiting illness for which the decision trajectory is often more clearly defined. These tools are distinct from the general population tools in Table 3a because they are more likely to focus on one ACP topic (6/8) and to be designed by a shared decisionmaking organization (6/8). These tools are more likely to meet decision aid criteria because the information they provide is more precise and targeted at specific decisions. However, two tools in Table 3b (Looking Ahead: Choices for Medical Care When You're Seriously Ill and the PEACE SERIES) are similar to the tools in Table 3a; they cover a number of general topics without a lot of depth. Although the tools in Table 3b are more likely to be designed by decisionmaking organizations (such as the Informed Medical Decisions Foundation and Healthwise) and to be reviewed by the Ottawa Hospital Research Institute, the tools do not appear in the published, peer reviewed literature. A disconnect exists between the gray literature tools and decision aids and the empirical literature.

### Context in Which ACP Decision Aids Are Used (Guiding Question 2)

Decision aids can better standardize the ACP process across facilitators or improve its efficiency. A variety of health care professionals, legal advisors, clergy, and even trained volunteers are available to facilitate ACP. When no decision aid is used, the facilitator's personal knowledge and biases have more opportunity to influence decisions. The facilitator's employer may also have financial incentives that influence which decision aids are used. For example, when a facilitator is employed or sponsored by a health care insurer, the business model of the insurer would possibly lead to decision aids that are biased towards limitations of treatment. Attorneys may find decision aids in ACP helpful given their lack of health care training. On the other hand, when a decision aid is used, the biases of its creators become relevant.

While attorneys typically charge an hourly rate for facilitation of ACP, reimbursement for health care provider time related to ACP is much more complex. Physicians, nurse practitioners, and physician assistants can select billing codes based on the amount of time they spend counselling patients for ACP, but only when such counselling takes up the majority of face-to-face time of an encounter. In all other cases, these providers as well as nurses, social workers, and chaplains who assist with ACP must consider facilitation of ACP as part of the overhead expense of the health care practice or institution, without separate or specific reimbursement. Several attempts to add ACP facilitation as a separate type of service into Medicare reimbursement policies have failed in Congress. This limitation in reimbursement inhibits many efforts to expand ACP, and reduces the willingness of health care institutions to invest in decision aid development or purchase, except where such tools improve efficiency of ACP or advance institutions' desired outcomes of ACP (e.g., fewer deaths in hospital).

Promotion and facilitation of ACP has been strongest in health crisis settings, when the “advance” part of ACP is hours to days. For example, the iconic SUPPORT study focused on decisionmaking in the intensive care unit.17,23,24 Similarly, ACP is heavily promoted in regulations for nursing homes, with advocacy for decisionmaking to take place at or near admission. Alternatively, shared decisionmaking for ACP can happen earlier in the course of an illness but after the patient develops a relationship with a trusted health care professional. Decision aids can be useful in all of these contexts, but most patients can best use such a tool before crises and with a strong patient-clinician relationship.

The POLST, which translates preferences resulting from ACP into a medical order, is intended primarily for those who have life expectancies less than 1 to 2 years. The form may be placed in a health care record or given to a patient to have available at home. A POLST provides explicit instructions from the signing physician to other physicians (e.g., in an emergency room), nurses, emergency medical personnel, and others. The POLST provides some legal and regulatory authorization to clinicians to provide or withhold emergency treatments without need for further discussion or need to obtain and review an advance directive. About one-third of States have statutes related to POLST. Decision aids to assist with the creation of a POLST form may be specific to the types of interventions addressed in a POLST, such as cardiopulmonary resuscitation, intubation for respiratory failure, and feeding tubes.

Hospitals, nursing homes, and some other health care programs are mandated to ask patients whether they have a health care directive. Recent clarifications in regulations require that nursing homes seek to determine patient preferences and enact processes to honor those preferences. Yet, no Federal or State mandates address the content or structure of ACP discussions; every State has statutes related to the documentation of preferences in health care directives.

Because State law governs almost all issues related to end-of-life care, decision aids for ACP should be consistent with a State's laws and regulations. For example, some States require that in order for a proxy to have authority regarding withholding or withdrawing a feeding tube, that preference must be explicitly stated in a health care directive, while other States grant a proxy discretion on that issue. Thus, an excellent decision aid for use in one State may mislead a patient's effort to document preferences in another State. This limits the ability of organizations to develop decision aids for ACP that contain enough detail for effective completion of an ACP process. Web sites such as FindLaw (http://statelaws.findlaw.com/minnesota-law/minnesota-durable-power-of-attorney-laws.html) and Caring Connections (http://www.caringinfo.org/i4a/pages/index.cfm?pageid=3289) provide examples of available resources.

## Evidence Map

### Current Evidence of ACP Decision Aids (Guiding Question 3)

As noted, the tools and decision aids found through gray literature search and consultation with Key Informants (Tables 3a and 3b) were not uncovered in the published literature search. The literature search yielded 363 articles. (Figure 2) Only 15 studies met the criteria for the correct patient population, intervention, and outcome measures.25-38 Studies that were excluded due to patient population included those that examined the use of end-of-life decision aids with families of chronic and critically ill newborns, children, and adolescents. The majority of studies were excluded based on lack of a decision aid intervention. These studies described or evaluated how patient, surrogate, or physician characteristics (race, health literacy, disability), structural components (culture of intensive care unit, education of physicians), economic incentives, or ethical considerations affect the end-of-life communications and care decisions, but did not include the use of a decision aid. Also excluded were studies that focused on decision theory or studies in which the primary outcomes of interest were the psychometric properties of a decision tool or aid. One study was excluded because the decision tool was for a research advance directive.39 A protocol for a randomized control trial was also excluded, as outcome information is not yet available.40 An additional study was located by searching for decision aids identified in the gray literature search, bringing the total included studies to 16.

Figure 2 Article flow diagram

Figure 2 illustrates the flow of articles through the screening process.

We identified an additional 10 ongoing studies from ClinicalTrials.gov and HRS-Proj databases (see Appendix C). However, 6 of the 10 trials appear to assess videos produced by ACP Decisions.

Evaluating the effectiveness of ACP decision aids is a relatively recent phenomenon, closely linked to the creation of criteria for patient decisionmaking in general. Fourteen of the 16 included studies were published within the last 5 years.

Details of the included studies are summarized in Tables 4 and 5 and discussed in the next sections.

Table 4 ACP decision aid studies

Study | Study Design | Population | Tool Name | Modality | Comparator
Volandes et al., 2012^36^ | Case series | 80 patients with advanced cancers | ACP Advanced Cancer Video | Video | Patients served as own control, before and after viewing video (all subjects received verbal description of care choices)
Deep et al., 2010^26^ | Case series | 120 community dwelling older adults | ACP Advanced Dementia Video | Video | Patients served as own control, before and after viewing video (all subjects received verbal description of care choices)
Volandes et al., 2009^37^ | Randomized controlled trial | 14 community dwelling older adults and their surrogates | ACP Advanced Dementia Video | Video | Patients randomized to verbal description only or verbal description with video decision aid
Volandes et al., 2009 (BMJ)38 | Randomized controlled trial | 200 community dwelling older adults | ACP Advanced Dementia Video | Video | Patients randomized to verbal description only or verbal description with video decision aid
Volandes et al., 2011^35^ | Randomized controlled trial | 76 community dwelling older adults | ACP Advanced Dementia Video | Video | Patients randomized to verbal description only or verbal description with video decision aid
Smith et al., 2011^33^ | Case series | 27 patients with advanced cancers | Adjuvant | Disease prognosis and probability statistics | Patients served as own control, before and after using decision aid
Allen et al., 2008^25^ | Randomized controlled trial | 78 community dwelling older adults | | Enhanced information on life-sustaining treatment risks, benefits, and alternatives | Patients randomized to medical information stimuli and the Life Support Preferences / Predictions Questionnaire (LSPQ) vignettes, or LSPQ vignettes only
Ditto et al., 2001^27^ | Randomized controlled trial | 401 community dwelling older adults | Health Care Directive (HCD) Valued Life Activities Directive (VLA) | Scenario-based advanced directive Value-based advanced directive | Patients randomized HCD no discussion, HCD with discussion, VLA no discussion, VLA with discussion, or no advance directive
Matlock et al., 2011^41^ | Randomized controlled trial | 51 inpatient palliative care patient or their decisionmaker | Looking Ahead: Choices for medical care when you're seriously ill | Booklet and DVD | Patients randomized to usual palliative consult services or usual care and the decision aid
Murphy et al., 2000^32^ | Case series | 31 community dwelling older adults | Making Decisions About Health Care | Interactive CD-ROM | Patients served as own control, before and after using decision aid
Green et al., 2009^28^ | Case series | 50 community dwelling older adults 34 patients with cancer | Making Your Wishes Known: Planning Your Medical Future | Self-directed computer program | Patients reported satisfaction and enhanced knowledge with use of aid.
Green et al., 2011^29^ | Randomized controlled trial | 121 community dwelling older adults 121 medical students | Making Your Wishes Known: Planning Your Medical Future | Self-directed computer program | Medical students and patients dyads were randomized to usual care or decision aid arms.
Hossler et al., 2011^30^ | Case series | 17 patients with amyotrophic lateral sclerosis (ALS) | Making Your Wishes Known: Planning Your Medical Future | Self-directed computer program | Patients served as own control, before and after using decision aid
Levi et al., 2011^31^ | Case series | 19 community dwelling older adults | Making Your Wishes Known: Planning Your Medical Future | Self-directed computer program | Evaluation of decision aid's ability to appropriately guide physician making
Song et al., 2005^34^ | Randomized controlled trial | 32 patients undergoing cardiac surgery and their surrogate | Patient-Centered Advance Care Planning | Structured interview | Patients randomized to usual advanced directive care (information packet and access to pastoral care facilitator) or decision aid
Vogel et al., 2013^42^ | Randomized controlled trial | 53 women with ovarian cancer were enrolled, 35 completed the study | | Self-directed computer program | Patients randomized to a control Web site with usual care information or the decision aid

Table 5 Outcomes examined by ACP decision aid studies

Study | Population | Modality | Tool Name | Satisfaction / Perceived Benefits of Tool | Care Intensity Consistent with Patient Preferences | AD or Disease Knowledge | Preference Stability Over Time | Reduce Decisional Conflict | Patient / Proxy Concordance | Patient / Doctor Concordance | Patient Hope | Patient Stress or Anxiety | AD Documentation / Palliative Consult
Volandes et al., 2012^36^ | Patients with advanced cancers | Video | ACP Advanced Cancer Video | + | NE | +
Deep et al., 2010^26^ | Community dwelling older adults | Video | ACP Advanced Dementia Video | + | + | +
Volandes et al., 2009^37^ | Community dwelling older adults | Video | ACP Advanced Dementia Video | + | + | +
Volandes et al., 2009 (BMJ)38 | Community dwelling older adults | Video | ACP Advanced Dementia Video | + | + | + | +
Volandes et al., 2011^35^ | Community dwelling older adults | Video | ACP Advanced Dementia Video | + | +
Smith et al., 2011^33^ | Patients with advanced cancers | Disease prognosis and probability statistics | Adjuvant | + | | + | | | | | NE | NE
Allen et al., 2008^25^ | Community dwelling older adults | Enhanced Information on life-sustaining treatment risks, benefits, and alternatives | | | +AA^*^ White | | | +
Ditto et al., 2001^27^ | Community dwelling older adults | Scenario-based AD Value-based AD | Health Care Directive (HCD) Valued Life Activities Directive (VLA) | + | NE | | | | NE
Matlock et al., 2011^41^ | Inpatient Palliative Care | Booklet and DVD | Looking Ahead: Choices for medical care when you're seriously ill | + | | NE | | NE
Murphy et al., 2000^32^ | Community dwelling older adults | Interactive CD-ROM | Making Decisions About Health Care | + | | +
Green et al., 2009^28^ | Community dwelling older adults Patients with cancer | Self-directed computer program | Making Your Wishes Known: Planning Your Medical Future | + | | + | | | | | NE | NE
Green et al., 2011^29^ | Community dwelling older adults Medical students | Self-directed computer program | Making Your Wishes Known: Planning Your Medical Future | + | | +
Hossler et al., 2011^30^ | Patients with amyotrophic lateral sclerosis (ALS) | Self-directed computer program | Making Your Wishes Known: Planning Your Medical Future | + | | +
Levi et al., 2011^31^ | Community dwelling older adults | Self-directed computer program | Making Your Wishes Known: Planning Your Medical Future | | | | | + | | +
Song et al., 2005^34^ | Patients undergoing cardiac surgery | Structured interview | Patient-Centered Advanced Care Planning | | | NE | | + | + | | | NE
Vogel et al., 2013^42^ | Patients with advanced ovarian cancer | Self-directed computer program | | NE | | | | NE | | | | | NE

AD= advance directive. NE=no effect found. AA=African American. +The study reported positive findings for that outcome. – The study reported negative findings for that outcome. Blank cell=not evaluated.

* African Americans differed from whites in preferences for receiving comfort care versus life sustaining care.

#### Study Designs

Of the 16 studies, 9 were RCTs25,27,29,34,35,37,38,41,42 and 7 were case-series.26,28,30-33,36 Two RCTs used a multiple treatment design.25,27 We could not determine whether harms information was systematically collected in many studies. Three studies included patient levels of stress and anxiety or hope to assess whether the use of the aid had increased distress as a side effect of using the tool.28,33,34

#### Patient Populations

The patient populations included in studies of decision aids for advance care planning include both patients with serious or advance illness and community-dwelling older adults or older adults without serious or advanced illness. This distinction is important: the valuation of health states changes with increasing age and experience of illness.10 Physicians treating a patient with advanced cancer may want to use a tool that has been studied in or designed for that population. Of the 16 included studies: 9 studies evaluated decision aids on community-dwelling older adults or older adult populations,25-27,29,31,32,35,37,38 6 evaluated decision aids on patients with serious or advanced illness,30,33,34,36,41,42 and 1 evaluated its decision aid on both general and disease specific populations.28 The nongeneral populations studied included patients with advanced cancers,28,33,36,42 patients undergoing cardiac surgery,34 and patients with amyotrophic lateral sclerosis (ALS),30 and inpatient palliative care.41 Many studies had additional inclusion criteria for age,25-27,34,35,37,38 language comprehension,25,29,32,35,38 level of cognitive functioning,25-27,30,35-38 availability of proxy,27,34,37 and presence of target condition.30,33,34,36 One study required participants to have access to a computer.42

#### Decision Aid Modalities

Decision aids took several forms: self-directed computer program or Web page,28-31,42 enhanced information,25 scenario-based AD,27 value-based AD,27 video depiction of patients with advanced disease,26,35,36,38 disease prognosis statistics,33 structured interview,34 interactive CD-ROM,32 and a DVD with an accompanying booklet.41 Eleven unique decision aids were studied. One of these, the self-directed computer program entitled “Making Your Wishes Known,” is directed at individuals rather than organizations, and is publicly available at https://www.makingyourwishesknown.com/default.aspx. Similarly, “Looking Ahead: Choices for Medical Care When You're Seriously Ill” is publicly available in streaming video format on the Informed Medical Decisions Foundation Web site: http://www.informedmedicaldecisions.org/imdf_decision_aid/choosing-medical-care-for-the-seriously-ill/.^a^ However, the video-based aids produced by the nonprofit foundation, ACP Decisions, (http://www.acpdecisions.org/videos/), and the structured Patient Centered Advance Care Planning interview are not for general public use; these tools are marketed toward specific health systems' beneficiaries. The former is a commercial product, primarily designed for health care organizations; the latter was created by such an organization. The cancer prognosis statistics decision aid is available in the original article appendix,33 and similar tools are available to physicians on the Adjuvant Web site (http://www.adjuvantonline.com/index.jsp). Three tools were described in the original articles but are not easily found in the public domain: the interactive CD-ROM,32 the enhanced information aid,25 a Web site intervention in pilot stage,42 the scenario-based AD, and the value-based AD.27

a During report preparation this decision aid became proprietary under a different organization. See http://www.healthdialog.com/Utility/News/PressRelease/14-01-17/Health_Dialog_and_the_Informed_Medical_Decisions_Foundation_Restructure_Longstanding_Relationship.aspx#

#### Comparators

The seven case-series studies had no comparison group by design.26,28,30-33,36 The comparison groups for the RCTs and controlled trials included control groups that received usual care,41 groups that received usual care in the same format as the intervention arm,42 groups that did not complete an advance directive,27 groups that were given advance directive forms without education or with written educational materials,29,34 or verbal and vignette description of conditions (without video enhancement).25,35,37,38 Green et al. (2011) provides an example of a clear description of usual care for advance directives: “This standard packet provides basic education about advance directives, sections for assigning a surrogate decisionmaker and outlining specific end-of-life wishes, along with instructions on how to complete the form. But it does not include values clarification exercises, education about medical conditions/treatments, or a decision support tool for assisting in decisionmaking” (page 84).29 This description is consistent with the definition of a decision aid used in this technical brief to identify appropriate gray literature tools.

#### Decision Aid Outcomes

Table 5 summarizes the assessed outcomes examined from the reviewed tools. Primary study outcomes include: patient satisfaction with decision aid or perceived helpfulness of decision aid (13/16), clarity regarding patient preference for comfort care (7/16), patient knowledge of advance directives or disease process (11/16), decisional conflict or confidence in decision (5/16), effect of tool on patient stress (3/16), patient/proxy decision concordance (2/16), effect of tool on patient hope (2/16), patient/physician decision concordance (1/16), preference stability over time (1/16), and advance directive documentation and scheduled consultation with palliative care (1/16). The studies report that while tools were generally well received and interpreted as helpful by patients, the effect of a decision aid on a patient's care choices and the communication of these choices to a health proxy or attending physician is mixed.

The nature of the outcomes that can be tested for ACPs depends on where the patient is on the continuum in Figure 1. Measures like “extending the patient's autonomy” can be tested only when the decision is imminent. Only three included studies evaluated the ability of the decision aid to improve surrogate decisionmaking or to increase the likelihood a patient's wishes being honored at the end of life.27,31,34

Some studies examined outcomes that can be assessed contemporaneously with the intervention, such as: whether participants felt their surrogates better understood their wishes, that the tools provided comfort to their surrogates,27 whether the use of a decision aid was helpful to patients,26,28-30,32,33,35-38 reduced decisional conflict,25,41,43 or increased patient knowledge of end-of-life decisions.26,32-34,36-38,41

In the following paragraphs we describe how satisfaction, decisional conflict, and education were assessed in the included studies, and we highlight validated tools with potential for standardizing evaluation.

##### Satisfaction/Helpfulness

Among the included studies, the most commonly evaluated outcome was satisfaction or perceived helpfulness of tool.26,28-30,32,33,35-38 A related outcome is the likelihood of a patient recommending the tool to a friend or person with the same health condition.35-38 Five studies evaluating the same tools, the ACP Decision videos, all reported percentages of participants in the intervention group finding the tool “very helpful” or “somewhat helpful” and the percentage of participants in the intervention group who would “definitely” or “probably” recommend the tool.26,35-38 One questionnaire simply asked if the information was helpful (yes or no).33 Matlock et al. (2011)41 was the only study to mention modifying an established shared decisionmaking acceptability tool. In addition to helpfulness of the decision aid and patient willingness to recommend it to a friend, the shared decisionmaking acceptability tool asks about the information provided including the amount, clarity, and viewpoint or neutrality41

##### Decisional Conflict/Sense of Control

Three included studies used different versions of the Decisional Conflict scale.25,41,43 The validated Decisional Conflict scale assesses patients' perceptions of uncertainty, modifiable factors contributing to the uncertainty, and ultimate satisfaction with choice.43 Hossler et al. (2011) adapted a self-determination scale developed by Pellino et al. (1998)44 to evaluate a distinct but related outcome: the patient's sense of control.30 Items on this scale included: “I can plan for my future medical needs,” “I can effectively communicate my wishes to my doctors,” and “I have the power to affect what happens to me in the future.”30

##### Knowledge

The educational assessments varied by target population. A video intervention focused on care choices for CPR and ventilation among terminal cancer patients asked six true/false questions including: “Most cancer patients who survive CPR and are placed on a breathing machine have very few complications from these procedures,” and “Most cancer patients that get CPR in the hospital survive and get to leave the hospital.”36 Murphy et al. (2000) also tested knowledge using the true or false format; the items included: “Draw up AD once you are ill to ensure accuracy,” “AD are only used to refuse treatment,” and “Avoid second guessing of your AD treatment preference.”32 Another study targeting cancer patients asked yes/ no questions (e.g., “Can this person with cancer in the bones and lymph nodes be cured by medical treatment?”), and asked participants to predict the likelihood of their cancer shrinking by half.33 Three studies measured participant perceptions of improved knowledge. Two studies used a Likert type scale to assess whether the participant believed knowledge was improved after using tool.37,38 One study provided percentages of participants mentioning educational outcomes after using the decision aid.26

##### Care Intensity Consistent With Patient Preferences

Five included studies evaluated the effect of the decision aid on increasing the likelihood a participant would choose less care.25,26,35-38 According to the IPDAS Collaboration, no clear treatment choice should apply to everyone; the best choice for end-of-life care is the amount of treatment that is consistent with a patient's values.9

### Evaluating ACP Decision Aids

The IPDAS Collaboration has developed criteria for evaluating the quality of a decision aid (http://ipdas.ohri.ca/IPDAS_checklist.pdf). In Table 6, we use the broad categories from the IPDAS checklist to identify the index question and briefly evaluate the quality of the decision aid content and development for the decision aid tools. We evaluate the identified decision aids from Table 3 and the published decision aids presented in Table 4.

Table 6 Evaluating ACP decision aids

| Index Decision | | | | Decision Aid Content | | | | | Decision Aid Development | | | | | Effectiveness
Name of Tool | Selection of Health Proxy | Preference for Multiple ACP Decisions | Preference for a Specific Life-Prolonging Treatment | Preference for Place of Care | Provide Information | Present Probabilities | Clarify Patient Values | Guide Decision Deliberation | Guide Decision Communication | Present Balanced Information | Systematic Development | Cite Scientific Evidence | Disclose COI | Use Plain Language | Decisions are Informed and Value Based
The Five Wishes | X | X | | | L | | X | | X | | | | | X
Consumer's Toolkit for Health Care Advanced Planning | X | X | | | M | | X | | X
Caring Connections: End of Life Decisions | X | X | | | M | | X
Caring Conversations | X | X | | | M | | X | X | X | | | | | X
CRITICAL Conditions Planning Guide | X | X | | | M | | X | | X | | | | | X
‘Thinking Ahead’ – GSF Advance Care Planning Discussion | X | X | | X | | | X | | X | | | | | X
PREPARE | X | X | | | H | | X | X | X | X | X
Should I have artificial hydration and nutrition? | | | X | | H | | X | X | X | X | X | X | X | X | M
Should I stop kidney dialysis? | | | X | | H | X | X | X | X | X | X | X | X | X | M
Should I receive CPR and life support? | | | X | | H | X | X | X | X | X | X | X | X | X | M
Should I stop treatment that prolongs my life? | | | X | | M | | X | X | X | X | X | | X | X | M
Looking Ahead: Choices for Medical Care When You're Seriously Ill | X | X | | | M | | X
When you need extra care, should you receive it at home or in a facility? | | | X | | M | | X | X | X | X | | | X | X
Adjuvant | | | X | | H | X | | X | | X | X | | X | X | M
Looking Ahead: Choices for Medical Care When You're Seriously Ill | X | X | | | M | | X | | | X
Making Your Wishes Known: Planning Your Medical Future | X | X | | | M | | X | | X | X | X | | X | | M

X=item was identified as present or met. L= Low; M = Medium; H = High.

An important component for the IPDAS decision aid evaluation is having an index decision. In evaluating ACP decision aids, we excluded tools with the main goal of prompting discussion of individual values for end-of-life care with loved ones and physicians. These questions, while important, do not equate to index decisions. Only three tools from the published literature could be evaluated using the IPDAS standards (Adjuvant, Making Your Wishes Known: Planning Your Medical Future, and Looking Ahead: Choices For Medical Care When You're Seriously Ill). The ACP Decisions videos depicted a woman with advanced Alzheimer's disease, but did not focus on a decision. A few of the decision aids were not publicly available.25,27,32 The Respecting Choices, Patient-Centered Advanced Care Planning interview is proprietary and used only by those completing proprietary training modules.

Compared with condition-specific aids, general decision aid tools that helped people choose a proxy and make advanced directive decisions provided less information about the index decisions. For the most part, advanced planning tools targeted at the general public were less likely to help people deliberate on their decision using a structured process. Two notable exceptions are the interactive online resources, PREPARE and MyDirectives. Both tools help patients deliberate and communicate their decisions, while providing considerable information and video examples for each decision.

The decision aid tools that focus on only one decision point are more likely to provide high levels of information and help the user deliberate or decide. Five of the decision-specific tools have been previously reviewed by the Ottawa Patient Decision Aid Research (OPDAR) using the IPDAS criteria. The content criteria can be evaluated by an individual viewing the tool, but the development criteria are less apparent on most of the organization Web sites. The five tools reviewed by OPDAR had this information available in their decision aid summaries, available on their Web site: http://decisionaid.ohri.ca/index.html.

Applying the IPDAS criteria to the decision aid tools highlights the general lack of effectiveness information. An effective decision aid leads to decisions (whether made by the patient or surrogate) that are informed and consistent with the decisionmaker's values. Few tools on the OPDAR Web site meet all effectiveness criteria. Generally available decision aids do not provide information to evaluate whether effectiveness has been assessed. For the decision aids found in the published effectiveness literature, the outcome measures are not effectiveness measures, as measured by the IPDAS, but measures of satisfaction and desire for comfort care over life-sustaining treatment. If comfort care is the choice that is consistent with the informed consumer's values and wishes, then the tool is effective. However, some informed consumers will have value systems that lead them to choose life sustaining care.

Key informants specified a set of important criteria for assessing decision aids. The first criterion is whether the decision aids are balanced, informing but not selling particular philosophical stances or specific decisions. The second criterion is whether decision aids present narratives of people who have gone through the experiences, particularly if several voices provide different perspectives to enhance the decision aid balance. The third criterion is making core facts available to reduce the likelihood of overestimating the value of interventions and the odds of good outcomes. Finally, decision aids should present relevant facts effectively and accessibly.