# Background

Advance care planning (ACP) can be thought about as a way to inform care choices when the patient cannot express a preference, but it is also a planning tool. Seriously ill patients' preferences regarding life-sustaining interventions depend on their goals for care. Some patients prioritize living longer to achieve life goals, while others may not wish to be kept alive when meaningful recovery or a particular quality of life is no longer possible.1-3 Religious and spiritual values and beliefs may also affect goals of care.4,5 Advance planning for future care helps to honor patient preferences and goals should incapacitating illness or injury prevent adequate communication.6

This Technical Brief considers decision aids that support the ACP process of decisionmaking for future health care needs. ACP generally has three components: (1) learning about anticipated condition(s) and the options for care, (2) considering those options, and (3) communicating preferences for future care, either orally or in writing. Ideally ACP should be included in general care planning, especially for those with complex needs. ACP can be facilitated by a health care provider but may also rely on self-administered tools or attorney-client discussions7 that focus on clarifying values and choosing a surrogate decisionmaker to serve when the person is incapacitated.

Decision aids help patients consider options in health care. We define ACP decision aids broadly as a form or a tool that includes a behavioral prompt. Aids should include at least three of the International Patient Decision Aid Standards (IPDAS) criteria: an educational component, a structured approach to thinking about choices, and a means of communicating those choices.8,9

An individual's health state at the time of planning determines the type of ACP decisions considered. Figure 1 illustrates a health state map based on quadrants in which we locate several common health states that trigger ACP activities. ACP decisions vary depending on the patient's location on the map, remaining life expectancy, and predictability of end-of-life care needs. Understanding what information to provide to support specific ACP treatment decisions generally improves as a person moves from left to right along this map and familiarity with health states increases. However, some disease states have more predictable trajectories than others, and uncertainty about which health states a person will face may persist.

Figure 1 Map of health states during which ACP may be considered

Figure 1 illustrates a health state map with several common health states that trigger ACP activities. One axis of the map ranges from hypothetical or proximity to the need for the clinical decision to an actual need for clinical decisions. The other axis captures the level of uncertainty the person has with regard to the decisions that will actually need to be made. The map shows the relative placement of individuals who are 1) healthy 2) facing a potentially life threatening illness 3) facing a life threatening illness or event 4) in hospice or 5) at the end of life. Healthy people engaged in estate planning may consider common decisions that arise near death, such as cardiopulmonary resuscitation, ventilator use, artificial nutrition/hydration, and hospice or comfort care. Some individuals may face additional decisions related to their specific health conditions or diseases.

Table 1 outlines how elements of decisionmaking can vary across the Figure 1 map. For example, healthy people may simply identify a proxy decisionmaker and offer some general values and preferences or care goals for various potential events. Those facing potentially life-threatening illness would focus concretely on how to manage emergency care. Those facing serious illness need to think about the likelihood of real benefits from different types of care and interventions and the probability of adverse events from treatment. Correspondingly, the type of information the decisionmaker needs most, and what the decision aid could provide, will vary. Most people gain clarity about what information can best support specific ACP treatment decisions as they move from hypothetical to actual clinical decisions and their familiarity with health states increases, or when the health state for which a decision is needed becomes more certain.

Table 1 Characteristics associated with ACP at various stages

| Stage of Health/Illness
| Healthy | Potentially Life Threatening Illness | Life Threatening Illness or Event | Hospice or Frail Elderly
Most relevant type of decision within ACP | Naming of proxy decisionmaker | Preferences for emergency management of acute life threatening event | Preferences for ongoing management of chronic illness in event of loss of decisional capacity, use of life support technology | Plan for site of death, preference for sedation versus physical comfort
Setting most common for ACP | Community event, on-line, or with attorney | Health care setting | Health care setting | Health care, hospice
Likelihood of ACP document actually informing an end of life decision | Low | Moderate | High | High
Type of information most needed in ACP decision aid | Role definition for proxy, criteria to consider proxy appropriateness | Probability of adverse event, outcomes with and without life sustaining efforts | Quantity and quality of life for those with advanced chronic illness, disease and intervention-specific benefits vs. burden of life support | Resources available to manage caregiver burden in various settings for end of life care, options for management of acute symptoms

For those not in end-of-life (EOL) situations, ACP decision aids prompt decisions for hypothetical health states they have not yet experienced. This requires people to imagine living with various conditions of disability. Often, however, people have only a tenuous understanding about the health states for which decisions are being made. For example, those imagining hypothetical disabilities consistently view them as more severe than those actually experiencing the disabilities, thus perhaps unknowingly exaggerating their own aversion to living with disability.10-13 As a result, if treatment-specific decision aids are used early in the Figure 1 map, healthy people may eschew treatment options that, in reality, they might willingly endure. ACP decisions differ from EOL decisions in which the patient tangibly (not hypothetically) experiences the consequences of their choices about treatments.

ACP, particularly among healthy older adults, is often undertaken outside of clinical settings. Nonclinical partners in shared decisionmaking may include other family members, caregivers, or attorneys or other professionals, rather than clinicians. Just as diverse populations are involved in ACP, many formats and types of decision aids are available to help patients and families with ACP. However, the empirical literature supporting decision aids for ACP is sparse, and a recent update of a Cochrane review on decision aids specifically excluded the hypothetical context of ACP decisions.14

This Technical Brief presents the “lay of the land” by describing the literature on ACP decision aids and offering a framework to help readers consider which decision aid best meets their needs. Thus, the Brief focuses on the decision aids themselves and the context within which they are used. It does not focus on the ACP decisionmaking process for patients or the tools or forms developed with the sole purpose of documenting advance directives or physician orders. Our Brief is focused solely on adults who are mentally and legally competent, because ACP (and the decision aids that support it) is so complex and encompasses diverse populations with widely varying health states. We excluded discussion of ACP for those who have never had the ability to participate in it, such as individuals with significant developmental disabilities and children. Decisionmaking by parents of gravely ill children differs qualitatively from decisionmaking for adult patients. Further, not only must children as legal minors rely on their parents to make decisions for them, but they may also not reach the age of majority and thus the ability to form their own legally binding decisions.

Opportunity for expansion and improvement of ACP remains. A 2003 Agency for Healthcare Research and Quality literature summary15 noted that less than 50 percent of the severely or terminally ill patients studied had in their medical records an advance directive, a common outcome of the advance care planning process.16-19 Further, only 12 percent of patients with an advance directive had received input from their physician in its development,17 and physicians were only about 65 percent accurate in predicting patient preferences and tended to think patients would want less life-prolonging treatment than they actually desired, even after reviewing the patient's advance directive.20 Decision aids may improve participation in ACP and the effectiveness of ACP communication by facilitating clear documentation across platforms and providers and by providing insights into why the patients made the decisions they did.