# Examples of Advanced Care Planning Tools That Did Not Meet Definition of Decision Aid

Organization | Name of Tool | Target Population | Description | Purpose of Tool | Tool Format | Accessed | URL
Gold Standards Framework | ‘Thinking Ahead’ – GSF Advance Care Planning Discussion | General planning before a medical event or terminal illness | Advance Statement should be used as a guide, to record what the patient DOES WISH to happen, to inform planning of care. This is a ‘dynamic’ planning document to be adapted and reviewed as needed and is in addition to Advanced Directives, Do Not Resuscitate plan, or other legal document. | Document patient wishes and prompt discussion | Downloadable form | Gold Standards Framework | http://www.goldstandardsframework.org.uk/advance-care-planning
ALS Association | ALS Respiratory Decisions | Patients with ALS | This pamphlet is designed to help the person with ALS make the choice or choices appropriate for them and their family. This information is for your education only and is not intended to replace the medical advice of your personal physician or other members of your health care team. | Document patient wishes and prompt discussion | Downloadable guide | The ALS Association Jim "Catfish" Hunter Chapter | http://webnc.alsa.org/site/DocServer/brochure_RespiratoryDecisions.pdf?docID