# Evidence Tables

Table D1 Gathered examples of commonly used or accessible decision aids

Name of Tool/Organization | Target Population | Description | Purpose of Tool | Tool Format
The Five Wishes/Aging with Dignity | General planning before a medical event or terminal illness | The Five Wishes document helps individuals express care options and preferences. The advance directive meets the legal requirements in most states and is available in 20 languages for a nominal fee. | AD education and completion | Order hard copy or complete online. Educational DVDs available.
Consumer's Toolkit for Health Care Advanced Planning/American Bar Association | General planning before a medical event or terminal illness | The toolkit does not create a formal advance directive for you. Instead, it helps you do the much harder job of discovering, clarifying, and communicating what is important to you in the face of serious illness. | AD education Clarify values | Downloadable guide
End-of-Life Decisions/Caring Connections | General planning before a medical event or terminal illness | This booklet addresses issues that matter to us all, because we will all face the end of life. Advance directives are valuable tools to help us communicate our wishes about our future medical care. | AD education | Downloadable guide
Caring Conversations/Center for Practical Bioethics | General planning before a medical event or terminal illness | Caring Conversations equips you with the tools you will need to communicate your wishes when you can no longer speak for yourself and advocate on your own behalf. The workbook includes a Durable Power of Attorney for Healthcare Decisions form and a Healthcare Treatment Directive form. | AD education and completion Conversation guide | Downloadable guide
Advanced Care Planning - Conversation Guide/Coalition for Compassionate Care of California | General planning before a medical event or terminal illness | The ACP conversation guide provides suggestions on how to raise the issue, responses to concerns your loved one might express, and questions to ask. | Conversation guide or prompts | Downloadable guide
Conversation Starter Kit and How to Talk to Your Doctor/Conversation Project, Institute for Healthcare Improvement | General planning before a medical event or terminal illness | The Conversation Project is dedicated to helping people talk about their wishes for end-of-life care with family members and physicians. | Conversation guide or prompts | Online resource and downloadable guides
Engage with Grace: The One Slide Project/Engage with Grace | General planning before a medical event or terminal illness | The One Slide Project was designed with one simple goal: to help get the conversation about end-of-life experience started. The idea is simple: create a tool to help get people talking. One Slide, with just five questions, is designed to help get us talking with each other and with our loved ones about our preferences. | Conversation guide or prompts | Web page with downloadable slide
CRITICAL Conditions Planning Guide/Georgia Health Decisions | General planning before a medical event or terminal illness | The CRITICAL Conditions Planning Guide walks you through advance care planning, beginning with meaningful conversations among your family members and resulting in the legal documentation of your preferences. | AD education and completion Conversation guide | Order hard copy or download
Preferred Priorities for Care (PPC)/Lancashire and South Cumbria Cancer Services Network | General planning before a medical event or terminal illness | The PPC document is recommended to help identify patient preferences for end-of-life care and prevent unwanted hospital admissions at the end of life. | Document patient wishes | Downloadable guide
PREPARE/The Regents of the University of California | General planning before a medical event or terminal illness | PREPARE is an interactive Web site serving as a resource for families navigating medical decisionmaking. PREPARE is a program that can help you: make medical decisions for yourself and others, talk with your doctors, and get the medical care that is right for you. | AD education and completion Conversation guide | Video/interactive online resource
PEACE Series/American College of Physicians | Patient with serious/advanced illness | The Consensus Panel project convened a second group of experts to develop patient education materials and Web content on end-of-life care. ACP's End-of-Life Care PEACE Series patient education brochures are available in print or to view online. | Conversation guide or prompts | Downloadable brochures
Should I have artificial hydration and nutrition?/Healthwise | Patients considering artificial hydration and nutrition if or when they are no longer able to take food or fluids by mouth | This decision aid helps patients decide whether or not to have artificial hydration and nutrition. | Education, value determination, document decision | Online resource
Questions to Ask Your Doctor About Advanced Cancer/National Cancer Institute at the NIH | Patients with advanced cancer | If you learn that you have advanced cancer, you may have choices to make about care and next steps. When you meet with your doctor, consider asking some of these questions. | Conversation guide or prompts | Online resource
Should I stop kidney dialysis?/Healthwise | Patients with kidney failure who have been undergoing dialysis, and for whom kidney transplantation is not possible | This decision aid helps patients decide whether to continue kidney dialysis, which will allow you to live longer, or stop kidney dialysis, which will allow death to occur naturally. | Education, value determination, document decision | Online resource
Should I receive CPR and life support?/Healthwise | Patients with serious/advanced illness | This decision aid helps patients decide whether or not to receive CPR and be put on a ventilator if heart or breathing stops. | Education, value determination, document decision | Online resource
Should I stop treatment that prolongs my life?/Healthwise | Patients with serious/advanced illness | This decision aid helps patients decide whether to stop treatment that prolongs life and instead receive only hospice care or not to stop treatment that prolongs life. | Education, value determination, document decision | Online resource
Looking Ahead: Choices for Medical Care When You're Seriously Ill/Informed Medical Decisions Foundation | Patients with serious/advanced illness | This program is for people with a serious illness that is, or may become, life threatening. This program is also for family members and caregivers. The program describes different types of medical care, such as palliative care and hospice care, and reviews various types of advance directives. | Education, value determination | Available as a DVD, a booklet, and a Web-based program
When you need extra care, should you receive it at home or in a facility?/Ottawa Patient Decision Aid Research Group | Patients with serious/advanced illness | This decision aid helps patients decide whether they would like to receive care at home or in a facility | Education, value determination, document decision | Downloadable pdf

Table D2 List of identified relevant studies from trial registries

Trial # (Registry) | Trial Name | Investigators Study Sponsor Collaborators
NCT01190488 (ClinicalTrials.gov-Completed) | Feasibility of an advanced care decision aid among patients and physicians | D Matlock University of Colorado, Denver
NCT01325519 (ClinicalTrials.gov-Recruiting) | A prospective randomized trial using video images in advanced care planning in seriously ill hospitalized patients | AE Volandes Massachusetts General Hospital
NCT01527331 (ClinicalTrials.gov-Recruiting) | A prospective trial using video images in advance care planning in hospitalized seriously ill patients with advanced cancer | AE Volandes Massachusetts General Hospital Stanford University
NCT01589120 (ClinicalTrials.gov-Recruiting) | Using videos to facilitate advance care planning for patients with heart failure (VIDEO-HF) | AE Volandes Massachusetts General Hospital University of Colorado, Denver, Vanderbilt University, South Shore Hospital, Brigham and Women's Hospital, Boston Medical Center
NCT01445145 (ClinicalTrials.gov-Completed) | An exploratory study of the use of Five Wishes as a tool for advanced care planning in young adults with metastatic, recurrent, or progressive cancer or HIV infection | L Wiener National Cancer Institute
NCT01105806 (ClinicalTrials.gov-Ongoing, not recruiting) | Cardiopulmonary resuscitation (CPR) video to enhance advance care planning in advanced upper gastrointestinal cancer patients | E O'Reilly Memorial Sloan-Kettering Cancer Center Massachusetts General Hospital, Mount Sinai Hospital, New York
NCT01391429 (ClinicalTrials.gov-Unknown) | Testing a video decision support tool to supplement goals-of-care discussions | M Paasche-Orlow, A Volandes Boston Medical Center
NCT01653938 (ClinicalTrials.gov-Recruiting) | A trial of a CPR video in heart failure patients | A Volandes Massachusetts General Hospital
HSRP20122281 (HRS-Proj – Ongoing) | Using videos to facilitate advance care planning for patients with heart failure | A Volandes Massachusetts General Hospital John D. Stoeckle Center for Primary Care Innovation, National Heart, Lung, and Blood Institute
HSRP20104051 (HSRProj – Ongoing) | Improving end-of-life care for cancer patients with video decision aids | A Volandes Massachusetts General Hospital Agency for Healthcare Research and Quality