# Organization Web sites Searched for Gray Literature

## Organization

Aging with Dignity

Allina Health

ALS Association

American Bar Association

American College of Physicians

Caring Connections

Center for Advanced Illness Coordinated Care, National Hospice and Palliative Care Organization

Center for Practical Bioethics

Coalition for Compassionate Care of California

Conversation Project, Institute for Healthcare Improvement

Deathwise

Engage with Grace

Georgia Health Decisions

Gold Standards Framework

Gundersen Health System, Respecting Choices

Healthwise

Henry Ford Health System

Honoring Choices Minnesota

Informed Medical Decisions Foundation

Lancashire and South Cumbria Cancer Services Network

Lifecare Directives, LLC

National Cancer Institute at the NIH

National Hospice and Palliative Care Organization

National POLST Paradigm Task Force

Ottawa Patient Decision Aid Research Group

PBS Religion & Ethics Newsweekly

Renal Palliative Care Initiative

Robert Wood Johnson Foundation, Promoting Excellence in End of Life Care

Sutter VNA and Hospice

The Huntington's Disease Workgroup of Promoting Excellence in End-of-Life Care

The Regents of the University of California