# Published Literature Search Strategy

We searched MEDLINE using the algorithm listed below. We adjusted the algorithm to also search the Cochrane Library, PsychINFO, and CINAHL databases.

Database: Ovid MEDLINE® <1946 to August Week 4 2013> Search Strategy:

1 | exp Advance Care Planning/
2 | exp Advance Directives/
3 | “advanced care plan*”.ti.
4 | “advance* care plan*”.m_titl.
5 | (advance* adj2 directive*).ti.
6 | “living will*”.m_titl.
7 | “end of life”.mp.
8 | exp Decision Support Techniques/
9 | exp Decision Support Systems, Clinical/
10 | decision aid*.mp.
11 | decision tool*.mp.
12 | decision support.mp.
13 | instrument*.ti,ab.
14 | intervention*.ti,ab.
15 | program*.ti,ab.
16 | exp *Decision Making/
17 | 13 or 14 or 15
18 | 15 and 16
19 | 8 or 9 or 10 or 11 or 12 or 18
20 | 1 or 2 or 3 or 4 or 5 or 6 or 7
21. | 19 and 20