# Interview Guides for Key Informants

## Questions for experts/researchers/provider organizations/practicing clinicians

a. What decision aids do you use in advance care planning?
b. What specific ACP tools and aids characterize your program? (May we see them?)
c. What do you see as the strengths and weaknesses of the decision aids you have used? The barriers and facilitators of using the decision aids?
d. Gray literature: which professional organizations are important to consult regarding:
  i. Tools
  ii. Preliminary study findings
e. Review/comment on definitions of ACP and decision aid models.
f. What types of research are needed most? What outcomes? What designs? When should outcomes be measured (length of followup)?
g. What format works best in your experience?
h. Which health care directive form do you prefer?

## Questions for patient advocates, families, caregivers

a. What information do patients need to know when planning advance care?
b. Does that information change based on your level of health?
c. What do you view as the advantages/disadvantages of advance planning?
d. How did the decision aid help with the planning process?

## Questions for ethicists/clergy/law

a. What do you consider important ethical considerations that need to be addressed with regard to ACP and decision aids?
b. How do decision aids help or change the dynamics of the ACP process itself, and, if conducted as a dialogue, discussions between patients, family members, and providers?
c. What information do you believe is most needed by people considering ACP?
d. What kinds of research would be most useful? What outcomes?
e. To what extent should the health care professional facilitating the conversation give advice (person as decision aid)?