# Summary and Implications

The issue of how to provide good transition care for children with special health care needs warrants further attention. The numbers of children with special health care needs reaching adulthood are increasing, and the diversity of their clinical conditions is expanding. The Got Transition38 resource provides a framework for transition care that can be adapted to serve the individual needs of a given patient population, but there is little evidence that it is used to provide a framework for evaluation in the research literature. Despite identifying numerous descriptions of existing transition programs or services, we identified only 24 evaluation studies.

Among the 25 studies, eight56,150,164-166,168,173,210,213 studied transition care for adolescents with diabetes. Five studies25,89,172,174,207 studied transition care in adolescents who had undergone organ transplant; all but one of these focused on kidney transplant. Two studied transition care in sickle cell disease.180,212 The remainder studied a variety of conditions including congenital adrenal hyperplasia,149 HIV,208 epilepsy,209 juvenile idiopathic arthritis,175,216 spina bifida,214 cystic fibrosis,148 inflammatory bowel disease,215 or included a patient population comprising more than one chronic disease.128, 211, 239

Twelve studies were conducted in Europe: eight in the United Kingdom,56,149,164,166,207,211,212,217 one in Germany,25 one in Spain,213 and two in Italy.150,173 Eight studies were conducted in the United States;128,148,165,174,180,212,214,239 three studies were conducted in Canada;89,168,209 and one study was conducted in Australia.172 One study included data from the United Kingdom and Australia.208 Interpretation of information from evaluation studies of transition care published in English from countries other than the United States must consider differences in the structure and financing of healthcare systems across countries.

Very few studies used a concurrent comparison group, although some compared survey responses of individuals who had participated in transition care with those of individuals who had not, with transition generally not occurring concurrently. This is because most interventions are implemented at the system level and provided to all relevant patients at the same time; thus, these studies generally relied on data from individuals who had previously transitioned before the services were available as comparators.

Outcomes were generally patient-reported and focused mostly on issues such as satisfaction with the process or health-related quality of life. Some clinical outcomes are available in the literature; these include objective measures such as glycosylated hemoglobin (HbA1c) levels for patients with diabetes and rates of organ rejection among transplant patients. Generally, however, successful transition is defined as attendance in adult care (transfer) or continued adherence to medication. Thus, although the programs offered comprehensive support rightly regarded as transition care, evaluation outcomes focused – at least in large part – on outcomes traditionally regarded as an index of the more limited concept of transfer.

Common components of care included use of a transition coordinator (6 studies), a special clinic for young adults in transition (8 studies) and provision of educational materials (12 studies), sometimes using computer-based programming.