# References

1 A consensus statement on health care transitions for young adults with special health care needs. Pediatrics. Dec. 2002;110(6 Pt 2):1304-6. [pmid: 12456949].
2 McPherson M, Arango P, Fox H, et al. A new definition of children with special health care needs. Pediatrics. Jul. 1998;102(1 Pt 1):137-40. [pmid: 9714637].
3 Goodman DM, Hall M, Levin A, et al. Adults with chronic health conditions originating in childhood: inpatient experience in children's hospitals. Pediatrics. Jul. 2011;128(1):5-13. [pmid: 21708805].
4 Scal P, Ireland M. Addressing transition to adult health care for adolescents with special health care needs. Pediatrics. Jun. 2005;115(6):1607-12. [pmid: 15930223].
5 Neff JM, Anderson G. Protecting children with chronic illness in a competitive marketplace. JAMA. Dec. 20. 1995;274(23):1866-9. [pmid: 7500537].
6 Newacheck PW, Kim SE. A national profile of health care utilization and expenditures for children with special health care needs. Arch Pediatr Adolesc Med. Jan. 2005;159(1):10-7. [pmid: 15630052].
7 Strickland BB, Singh GK, Kogan MD, et al. Access to the medical home: new findings from the 2005-2006 National Survey of Children with Special Health Care Needs. Pediatrics. Jun. 2009;123(6):e996-1004. [pmid: 19482751].
8 Transition of care provided for adolescents with special health care needs. American Academy of Pediatrics Committee on Children with Disabilities and Committee on Adolescence. Pediatrics. Dec. 1996;98(6 Pt 1):1203-6. [pmid: 8951283].
9 Gortmaker SL, Sappenfield W. Chronic childhood disorders: prevalence and impact. Pediatr Clin North Am. Feb. 1984;31(1):3-18. [pmid: 6366717].
10 Perrin JM, Bloom SR, Gortmaker SL. The increase of childhood chronic conditions in the United States. JAMA. Jun. 27. 2007;297(24):2755-9. [pmid: 17595277].
11 Horner-Johnson W, Newton K. Using Population-Based Survey Data to Monitor the Health of Children and Youth with Special Health Care Needs and Disabilities. Hollar D, editor. Handbook of Children with Special Health Care Needs. Springer. New York. 2012:307-34.
12 Pollack L, McManus M. Special Analysis of the 2009/10 National Survey of Children with Special Health Care Needs by Lauren Pollack and Margaret McManus of the National Alliance to Advance Adolescent Health. March. 2012.
13 Stoeck PA, Cheng N, Berry AJ, et al. Health care transition counseling for youth with special health care needs. Am Fam Physician. Dec. 1. 2012;86(11):1024. [pmid: 23198669].
14 McManus MA, Pollack LR, Cooley WC, et al. Current status of transition preparation among youth with special needs in the United States. Pediatrics. Jun. 2013;131(6):1090-7. [pmid: 23669518].
15 Toomey SL, Chien AT, Elliott MN, et al. Disparities in unmet need for care coordination: the national survey of children's health. Pediatrics. Feb. 2013;131(2):217-24. [pmid: 23339228].
16 Kane DJ, Kasehagen L, Punyko J, et al. What factors are associated with state performance on provision of transition services to CSHCN?. Pediatrics. Dec. Suppl 4. 2009;124:S375-83. [pmid: 19948602].
17 Richmond N, Tran T, Berry S. Receipt of transition services within a medical home: do racial and geographic disparities exist?. Matern Child Health J. Aug. 2011;15(6):742-52. [pmid: 20602158].
18 Richmond NE, Tran T, Berry S. Can the Medical Home eliminate racial and ethnic disparities for transition services among Youth with Special Health Care Needs?. Matern Child Health J. May. 2012;16(4):824-33. [pmid: 21505782].
19 Reiss J. Health care transition for emerging adults with chronic health conditions and disabilities. Pediatr Ann. Oct. 2012;41(10):429-35. [pmid: 23052147].
20 White PH, McManus MA, McAllister JW, et al. A primary care quality improvement approach to health care transition. Pediatr Ann. May. 2012;41(5):e1-7. [pmid: 22587507].
21 Lotstein DS, McPherson M, Strickland B, et al. Transition planning for youth with special health care needs: results from the National Survey of Children with Special Health Care Needs. Pediatrics. Jun. 2005;115(6):1562-8. [pmid: 15930217].
22 Hazel E, Zhang X, Duffy CM, et al. High rates of unsuccessful transfer to adult care among young adults with juvenile idiopathic arthritis. Pediatr Rheumatol Online J. 2010;8:2. [pmid: 20148143].
23 Nakhla M, Daneman D, To T, et al. Transition to adult care for youths with diabetes mellitus: findings from a Universal Health Care System. Pediatrics. Dec. 2009;124(6):e1134-41. [pmid: 19933731].
24 Okumura MJ, Heisler M, Davis MM, et al. Comfort of general internists and general pediatricians in providing care for young adults with chronic illnesses of childhood. J Gen Intern Med. Oct. 2008;23(10):1621-7. [pmid: 18661191].
25 Pape L, Lammermuhle J, Oldhafer M, et al. Different models of transition to adult care after pediatric kidney transplantation: A comparative study. Pediatr Transplant. Sep. 2013;17(6):518-24. [pmid: 23730905].
26 Taylor A, Lizzi M, Marx A, et al. Implementing a care coordination program for children with special healthcare needs: partnering with families and providers. J Healthc Qual. Sep. 2013;35(5):70-7. [pmid: 22913270].
27 Schrander-Stumpel CT, Sinnema M, van den Hout L, et al. Healthcare transition in persons with intellectual disabilities: general issues, the Maastricht model, and Prader-Willi syndrome. Am J Med Genet C Semin Med Genet. Aug. 15. 2007;145C(3):241-7. [pmid: 17639594].
28 Peter NG, Forke CM, Ginsburg KR, et al. Transition from pediatric to adult care: internists' perspectives. Pediatrics. Feb. 2009;123(2):417-23. [pmid: 19171604].
29 Patel MS, O'Hare K. Residency training in transition of youth with childhood-onset chronic disease. Pediatrics. Dec. Suppl 3. 2010;126:S190-3. [pmid: 21123485].
30 McManus Mea. Pediatric perspectives and Practices on Transitioning Adolescents with Special health Care Needs to Adult Health Care. Washington DC. National Alliance to Advance Adolescent Health. 2008.
31 Callahan ST, Cooper WO. Continuity of health insurance coverage among young adults with disabilities. Pediatrics. Jun. 2007;119(6):1175-80. [pmid: 17545386].
32 National Center for Health Statistics. Healthy People 2010 Final Review: Disability and secondary conditions. U.S. Department of Health and Human Services. DHHS publication no. (PHS)2012–1038. Hyattsville, MD. 2012. http://www.cdc.gov/nchs/healthy_people/hp2010/hp2010_final_review.htm.
33 U.S. Department of Health and Human Services, Health Resources and Services Administration, Maternal and Child Health Bureau. The National Survey of Children with special health care needs chartbook 2005-2006. 2006.
34 Bloom SR, Kuhlthau K, Van Cleave J, et al. Health care transition for youth with special health care needs. J Adolesc Health. Sep. 2012;51(3):213-9. [pmid: 22921130].
35 Patient Protection and Affordable Care Act. 42 USC § 18001. 2010.
36 Cooley WC, Sagerman PJ. Supporting the health care transition from adolescence to adulthood in the medical home. Pediatrics. Jul. 2011;128(1):182-200. [pmid: 21708806].
37 Got Transition?. Tools: Six Core Elements of Health Care Transition and Health Care Transition Index. http://www.gottransition.org/6-core-elements.
38 Got Transition?. Center for Health Care Transition Improvement National Alliance to Advance Adolescent Health. http://www.gottransition.org/.
39 Rosen DS, Blum RW, Britto M, et al. Transition to adult health care for adolescents and young adults with chronic conditions: position paper of the Society for Adolescent Medicine. J Adolesc Health. Oct. 2003;33(4):309-11. [pmid: 14519573].
40 McDonagh JE, Foster HE, Hall MA, et al. Audit of rheumatology services for adolescents and young adults in the UK. British Paediatric Rheumatology Group. Rheumatology (Oxford). Jun. 2000;39(6):596-602. [pmid: 10888703].
41 Bobo N, Butler S. The transition from pediatric to adult diabetes health care. NASN Sch Nurse. May. 2010;25(3):114-5. [pmid: 20486445].
42 Bell LE, Sawyer SM. Transition of care to adult services for pediatric solid-organ transplant recipients. Pediatr Clin North Am. Apr. 2010;57(2):593-610. table of contents. [pmid: 20371054].
43 McDonagh JE. Growing up and moving on: transition from pediatric to adult care. Pediatr Transplant. Jun. 2005;9(3):364-72. [pmid: 15910395].
44 Shaw KL, Southwood TR, McDonagh JE. Transitional care for adolescents with juvenile idiopathic arthritis: a Delphi study. Rheumatology (Oxford). Aug. 2004;43(8):1000-6. [pmid: 15150431].
45 Scal P. Transition for youth with chronic conditions: primary care physicians' approaches. Pediatrics. Dec. 2002;110(6 Pt 2):1315-21. [pmid: 12456951].
46 Srivastava SA, Elkin SL, Bilton D. The transition of adolescents with chronic respiratory illness to adult care. Paediatr Respir Rev. Dec. 2012;13(4):230-5. quiz 5. [pmid: 23069122].
47 van Dyck PC, Kogan MD, McPherson MG, et al. Prevalence and characteristics of children with special health care needs. Arch Pediatr Adolesc Med. Sep. 2004;158(9):884-90. [pmid: 15351754].
48 Lerret SM, Menendez J, Weckwerth J, et al. Essential components of transition to adult transplant services: the transplant coordinators' perspective. Prog Transplant. Sep. 2012;22(3):252-8. [pmid: 22951502].
49 Schwartz LA, Tuchman LK, Hobbie WL, et al. A social-ecological model of readiness for transition to adult-oriented care for adolescents and young adults with chronic health conditions. Child Care Health Dev. Nov. 2011;37(6):883-95. [pmid: 22007989].
50 Grant C, Pan J. A comparison of five transition programmes for youth with chronic illness in Canada. Child Care Health Dev. Nov. 2011;37(6):815-20. [pmid: 22007981].
51 Herzer M, Goebel J, Cortina S. Transitioning cognitively impaired young patients with special health needs to adult-oriented care: collaboration between medical providers and pediatric psychologists. Curr Opin Pediatr. Oct. 2010;22(5):668-72. [pmid: 20601881].
52 Viner RM. Transition of care from paediatric to adult services: one part of improved health services for adolescents. Arch Dis Child. Feb. 2008;93(2):160-3. [pmid: 17942588].
53 Knauth A, Verstappen A, Reiss J, et al. Transition and transfer from pediatric to adult care of the young adult with complex congenital heart disease. Cardiol Clin. Nov. 2006;24(4):619-29. vi. [pmid: 17098515].
54 Pinzon JL, Jacobson K, Reiss J. Say goodbye and say hello: the transition from pediatric to adult gastroenterology. Can J Gastroenterol. Dec. 2004;18(12):735-42. [pmid: 15605138].
55 Betz CL. Nurse's role in promoting health transitions for adolescents and young adults with developmental disabilities. Nurs Clin North Am. Jun. 2003;38(2):271-89. [pmid: 12914308].
56 Kipps S, Bahu T, Ong K, et al. Current methods of transfer of young people with Type 1 diabetes to adult services. Diabet Med. Aug. 2002;19(8):649-54. [pmid: 12147145].
57 Cervia JS. Easing the Transition of HIV-Infected Adolescents to Adult Care. AIDS Patient Care STDS. Dec. 2013;27(12):692-6. [pmid: 24073595].
58 Ryan S. The adolescent and young adult with Klinefelter syndrome:ensuring successful transitions to adulthood. Pediatr Endocrinol Rev. Dec. Suppl 1. 2010;8:169-77. [pmid: 21217609].
59 Tuchman LK, Schwartz LA, Sawicki GS, et al. Cystic fibrosis and transition to adult medical care. Pediatrics. Mar. 2010;125(3):566-73. [pmid: 20176665].
60 Betz CL. Transition of adolescents with special health care needs: review and analysis of the literature. Issues Compr Pediatr Nurs. Jul-Sep. 2004;27(3):179-241. [pmid: 15371115].
61 Nobili RM, Duff AJ, Ullrich G, et al. Guiding principles on how to manage relevant psychological aspects within a CF team: interdisciplinary approaches. J Cyst Fibros. Jun. Suppl 2. 2011;10:S45-52. [pmid: 21658641].
62 Towns SJ, Bell SC. Transition of adolescents with cystic fibrosis from paediatric to adult care. Clin Respir J. Apr. 2011;5(2):64-75. [pmid: 21410898].
63 Kennedy A, Sloman F, Douglass JA, et al. Young people with chronic illness: the approach to transition. Intern Med J. Aug. 2007;37(8):555-60. [pmid: 17640188].
64 Robertson L. When should young people with chronic rheumatic disease move from paediatric to adult-centred care?. Best Pract Res Clin Rheumatol. Apr. 2006;20(2):387-97. [pmid: 16546063].
65 Robb A, Findling RL. Challenges in the transition of care for adolescents with attention-deficit/hyperactivity disorder. Postgrad Med. Jul. 2013;125(4):131-40. [pmid: 23933901].
66 Jalkut MK, Allen PJ. Transition from pediatric to adult health care for adolescents with congenital heart disease: a review of the literature and clinical implications. Pediatr Nurs. Nov-Dec. 2009;35(6):381-7. [pmid: 20166468].
67 Sawicki GS, Lukens-Bull K, Yin X, et al. Measuring the transition readiness of youth with special healthcare needs: validation of the TRAQ--Transition Readiness Assessment Questionnaire. J Pediatr Psychol. Mar. 2011;36(2):160-71. [pmid: 20040605].
68 Suris JC, Akre C, Rutishauser C. How adult specialists deal with the principles of a successful transition. J Adolesc Health. Dec. 2009;45(6):551-5. [pmid: 19931826].
69 Betz CL, Redcay G. Creating Healthy Futures: an innovative nurse-managed transition clinic for adolescents and young adults with special health care needs. Pediatr Nurs. Jan-Feb. 2003;29(1):25-30. [pmid: 12630502].
70 Callahan ST, Winitzer RF, Keenan P. Transition from pediatric to adult-oriented health care: a challenge for patients with chronic disease. Curr Opin Pediatr. Aug. 2001;13(4):310-6. [pmid: 11717554].
71 Crowley R, Wolfe I, Lock K, et al. Improving the transition between paediatric and adult healthcare: a systematic review. Arch Dis Child. Jun. 2011;96(6):548-53. [pmid: 21388969].
72 Treadwell M, Telfair J, Gibson RW, et al. Transition from pediatric to adult care in sickle cell disease: establishing evidence-based practice and directions for research. Am J Hematol. Jan. 2011;86(1):116-20. [pmid: 21061308].
73 Fegran L, Hall EO, Uhrenfeldt L, et al. Adolescents' and young adults' transition experiences when transferring from paediatric to adult care: A qualitative metasynthesis. Int J Nurs Stud. Jan. 2014;51(1):123-35. [pmid: 23490470].
74 Hudsmith LE, Thorne SA. Transition of care from paediatric to adult services in cardiology. Arch Dis Child. Oct. 2007;92(10):927-30. [pmid: 17895343].
75 Eleftheriou D, Isenberg DA, Wedderburn LR, et al. The coming of age of adolescent rheumatology. Nat Rev Rheumatol. 2014. Jan. 7. [pmid: 24394351].
76 Kovacs AH, Verstappen A. The whole adult congenital heart disease patient. Prog Cardiovasc Dis. Jan-Feb. 2011;53(4):247-53. [pmid: 21295666].
77 Campbell T, Beer H, Wilkins R, et al. “I look forward. I feel insecure but I am ok with it”. The experience of young HIV+ people attending transition preparation events: a qualitative investigation. AIDS Care. Feb. 2010;22(2):263-9. [pmid: 20390505].
78 Hilderson D, Westhovens R, Wouters C, et al. Rationale, design and baseline data of a mixed methods study examining the clinical impact of a brief transition programme for young people with juvenile idiopathic arthritis: the DON'T RETARD project. BMJ Open. 2013;3(12):e003591. [pmid: 24302502].
79 Lyons SK, Libman IM, Sperling MA. Diabetes in the adolescent: transitional issues. J Clin Endocrinol Metab. Dec. 2013;98(12):4639-45. [pmid: 24152689].
80 Swift KD, Sayal K, Hollis C. ADHD and transitions to adult mental health services: a scoping review. Child Care Health Dev. 2013. Oct. 25. [pmid: 24164052].
81 Lochridge J, Wolff J, Oliva M, et al. Perceptions of solid organ transplant recipients regarding self-care management and transitioning. Pediatr Nurs. Mar-Apr. 2013;39(2):81-9. [pmid: 23705299].
82 Kaufmann Rauen K, Sawin KJ, Bartelt T, et al. Transitioning adolescents and young adults with a chronic health condition to adult healthcare - an exemplar program. Rehabil Nurs. Mar-Apr. 2013;38(2):63-72. [pmid: 23529944].
83 Fair CD, Sullivan K, Gatto A. Best practices in transitioning youth with HIV: perspectives of pediatric and adult infectious disease care providers. Psychol Health Med. Oct. 2010;15(5):515-27. [pmid: 20835962].
84 Brumfield K, Lansbury G. Experiences of adolescents with cystic fibrosis during their transition from paediatric to adult health care: a qualitative study of young Australian adults. Disabil Rehabil. Feb. 18. 2004;26(4):223-34. [pmid: 15164956].
85 Wiener LS, Kohrt BA, Battles HB, et al. The HIV experience: youth identified barriers for transitioning from pediatric to adult care. J Pediatr Psychol. Mar. 2011;36(2):141-54. [pmid: 20040607].
86 Majumdar S. The adolescent with sickle cell disease. Adolesc Med State Art Rev. Apr. 2013;24(1):295-306. xv. [pmid: 23705531].
87 Jordan L, Swerdlow P, Coates TD. Systematic review of transition from adolescent to adult care in patients with sickle cell disease. J Pediatr Hematol Oncol. Apr. 2013;35(3):165-9. [pmid: 23511487].
88 Sobota A, Neufeld EJ, Sprinz P, et al. Transition from pediatric to adult care for sickle cell disease: results of a survey of pediatric providers. Am J Hematol. Jun. 2011;86(6):512-5. [pmid: 21594889].
89 Prestidge C, Romann A, Djurdjev O, et al. Utility and cost of a renal transplant transition clinic. Pediatr Nephrol. Feb. 2012;27(2):295-302. [pmid: 21823039].
90 Webb N, Harden P, Lewis C, et al. Building consensus on transition of transplant patients from paediatric to adult healthcare. Arch Dis Child. Aug. 2010;95(8):606-11. [pmid: 20515964].
91 Bowen ME, Henske JA, Potter A. Health care transition in adolescents and young adults with diabetes. Clinical Diabetes. 2010;28(3):99-106.
92 Young S, Murphy CM, Coghill D. Avoiding the ‘twilight zone’: recommendations for the transition of services from adolescence to adulthood for young people with ADHD. BMC Psychiatry. 2011;11:174. [pmid: 22051192].
93 Mennito SH, Clark JK. Transition medicine: a review of current theory and practice. South Med J. Apr. 2010;103(4):339-42. [pmid: 20224504].
94 Tucker LB, Cabral DA. Transition of the adolescent patient with rheumatic disease: issues to consider. Pediatr Clin North Am. Apr. 2005;52(2):641-52. viii. [pmid: 15820382].
95 Betz CL. Health care transition for adolescents with special healthcare needs: where is nursing?. Nurs Outlook. Sep-Oct. 2013;61(5):258-65. [pmid: 23036691].
96 Boyle MP, Farukhi Z, Nosky ML. Strategies for improving transition to adult cystic fibrosis care, based on patient and parent views. Pediatr Pulmonol. Dec. 2001;32(6):428-36. [pmid: 11747245].
97 Transitioning HIV-infected youth into adult health care. Pediatrics. Jul. 2013;132(1):192-7. [pmid: 23796739].
98 Gleeson H, Turner G. Transition to adult services. Arch Dis Child Educ Pract Ed. Jun. 2012;97(3):86-92. [pmid: 21979963].
99 Watson AR, Harden PN, Ferris ME, et al. Transition from pediatric to adult renal services: a consensus statement by the International Society of Nephrology (ISN) and the International Pediatric Nephrology Association (IPNA). Kidney Int. Oct. 2011;80(7):704-7. [pmid: 21832978].
100 Hanna KM, Woodward J. The transition from pediatric to adult diabetes care services. Clin Nurse Spec. May-Jun. 2013;27(3):132-45. [pmid: 23575170].
101 McDonagh JE, Shaw KL, Southwood TR. Growing up and moving on in rheumatology: development and preliminary evaluation of a transitional care programme for a multicentre cohort of adolescents with juvenile idiopathic arthritis. J Child Health Care. Mar. 2006;10(1):22-42. [pmid: 16464931].
102 Lebensburger JD, Bemrich-Stolz CJ, Howard TH. Barriers in transition from pediatrics to adult medicine in sickle cell anemia. J Blood Med. 2012;3:105-12. [pmid: 23055784].
103 McDonagh J, Gleeson H. Getting transition right for young people with diabetes. European Diabetes Nursing. 2011;8(1):24.
104 Stewart D. Transition to adult services for young people with disabilities: current evidence to guide future research. Dev Med Child Neurol. Oct. Suppl 4. 2009;51:169-73. [pmid: 19740226].
105 Tattersall RS. The MAGICC and practical approach to rheumatology transition. Br J Hosp Med (Lond). Oct. 2012;73(10):552-7. [pmid: 23124284].
106 Lewis K. All grown up: moving from pediatric to adult diabetes care. Am J Med Sci. Apr. 2013;345(4):278-83. [pmid: 23531959].
107 Ross HM, Fleck D. Clinical considerations for allied professionals: issues in transition to adult congenital heart disease programs. Heart Rhythm. Jun. 2007;4(6):811-3. [pmid: 17556212].
108 de Montalembert M, Guitton C. Transition from paediatric to adult care for patients with sickle cell disease. Br J Haematol. 2013. Dec. 17. [pmid: 24345037].
109 Harden PN, Sherston SN. Optimal management of young adult transplant recipients: the role of integrated multidisciplinary care and peer support. Ann Saudi Med. Sep-Oct. 2013;33(5):489-91. [pmid: 24188944].
110 Transition to adult care for youth with special health care needs. Paediatr Child Health. Nov. 2007;12(9):785-93. [pmid: 19030468].
111 Sobus KML, Karkos JB. Rehabilitation care and management for the individual with cerebral palsy, ages 13 through early adulthood. Critical Reviews in Physical & Rehabilitation Medicine. 2009;21(2):117-65.
112 Binks JA, Barden WS, Burke TA, et al. What do we really know about the transition to adult-centered health care? A focus on cerebral palsy and spina bifida. Arch Phys Med Rehabil. Aug. 2007;88(8):1064-73. [pmid: 17678671].
113 Reider-Demer M, Zielinski T, Carvajal S, et al. When is a pediatric patient no longer a pediatric patient?. J Pediatr Health Care. Jul-Aug. 2008;22(4):267-9. [pmid: 18590875].
114 Viner R. Barriers and good practice in transition from paediatric to adult care. J R Soc Med. Suppl 40. 2001;94:2-4. [pmid: 11601160].
115 Greene S, Greene A. Changing from the paediatric to the adult service: guidance on the transition of care. Practical Diabetes International. 2005;22(2):41-5.
116 Sable C, Foster E, Uzark K, et al. Best practices in managing transition to adulthood for adolescents with congenital heart disease: the transition process and medical and psychosocial issues: a scientific statement from the American Heart Association. Circulation. Apr. 5. 2011;123(13):1454-85. [pmid: 21357825].
117 Madge S, Bryon M. A model for transition from pediatric to adult care in cystic fibrosis. J Pediatr Nurs. Aug. 2002;17(4):283-8. [pmid: 12219328].
118 Betz CL, Lobo ML, Nehring WM, et al. Voices not heard: a systematic review of adolescents' and emerging adults' perspectives of health care transition. Nurs Outlook. Sep-Oct. 2013;61(5):311-36. [pmid: 23876260].
119 Berg Kelly K. Sustainable transition process for young people with chronic conditions: a narrative summary on achieved cooperation between paediatric and adult medical teams. Child Care Health Dev. Nov. 2011;37(6):800-5. [pmid: 22007979].
120 Parfitt G. Proving young person's experience transition: lessons from Wales. Paediatr Nurs. Nov. 2008;20(9):27-30. [pmid: 19006948].
121 Nazareth D, Walshaw M. Coming of age in cystic fibrosis - transition from paediatric to adult care. Clin Med. Oct. 2013;13(5):482-6. [pmid: 24115706].
122 Lewis-Gary MD. Transitioning to adult health care facilities for young adults with a chronic condition. Pediatr Nurs. Sep-Oct. 2001;27(5):521-4. [pmid: 12025316].
123 Lemly DC, Weitzman ER, O'Hare K. Advancing healthcare transitions in the medical home: tools for providers, families and adolescents with special healthcare needs. Curr Opin Pediatr. Aug. 2013;25(4):439-46. [pmid: 23770924].
124 Hall CL, Newell K, Taylor J, et al. ‘Mind the gap’--mapping services for young people with ADHD transitioning from child to adult mental health services. BMC Psychiatry. 2013;13:186. [pmid: 23842080].
125 Shaw KL, Southwood TR, McDonagh JE. Developing a programme of transitional care for adolescents with juvenile idiopathic arthritis: results of a postal survey. Rheumatology (Oxford). Feb. 2004;43(2):211-9. [pmid: 14523224].
126 Applebaum MA, Lawson EF, von Scheven E. Perception of transition readiness and preferences for use of technology in transition programs: teens' ideas for the future. Int J Adolesc Med Health. 2013;25(2):119-25. [pmid: 23740658].
127 Christie D, Viner R. Chronic illness and transition: time for action. Adolesc Med State Art Rev. Dec. 2009;20(3):981-7. xi. [pmid: 20653213].
128 Maslow G, Adams C, Willis M, et al. An evaluation of a positive youth development program for adolescents with chronic illness. J Adolesc Health. Feb. 2013;52(2):179-85. [pmid: 23332482].
129 Amaria K, Stinson J, Cullen-Dean G, et al. Tools for addressing systems issues in transition. Healthc Q. Oct. 2011;14(Spec No 3):72-6. [pmid: 22008577].
130 Allen D, Cohen D, Hood K, et al. Continuity of care in the transition from child to adult diabetes services: a realistic evaluation study. J Health Serv Res Policy. Jul. 2012;17(3):140-8. [pmid: 22767889].
131 Ferris ME, Mahan JD. Pediatric chronic kidney disease and the process of health care transition. Semin Nephrol. Jul. 2009;29(4):435-44. [pmid: 19615564].
132 Duke NN, Scal PB. Adult care transitioning for adolescents with special health care needs: a pivotal role for family centered care. Matern Child Health J. Jan. 2011;15(1):98-105. [pmid: 20012347].
133 Helgeson VS, Reynolds KA, Snyder PR, et al. Characterizing the transition from paediatric to adult care among emerging adults with Type 1 diabetes. Diabet Med. May. 2013;30(5):610-5. [pmid: 23157171].
134 McDonagh JE, Shaw KL. Adolescent rheumatology transition care in the UK. Pediatr Ann. May. 2012;41(5):e8-15. [pmid: 22587509].
135 Breakey VR, Blanchette VS, Bolton-Maggs PH. Towards comprehensive care in transition for young people with haemophilia. Haemophilia. Nov. 2010;16(6):848-57. [pmid: 20491954].
136 Stille CJ. Communication, comanagement, and collaborative care for children and youth with special healthcare needs. Pediatr Ann. Sep. 2009;38(9):498-504. [pmid: 19772236].
137 Reiss J, Gibson R. Health care transition: destinations unknown. Pediatrics. Dec. 2002;110(6 Pt 2):1307-14. [pmid: 12456950].
138 Karas DJ, Costain G, Chow EW, et al. Perceived burden and neuropsychiatric morbidities in adults with 22q11.2 deletion syndrome. J Intellect Disabil Res. Feb. 2014;58(2):198-210. [pmid: 23106770].
139 Field B, Scheinberg A, Cruickshank A. Health care services for adults with cerebral palsy. Aust Fam Physician. Mar. 2010;39(3):165-7. [pmid: 20369122].
140 Monaghan M, Hilliard M, Sweenie R, et al. Transition readiness in adolescents and emerging adults with diabetes: the role of patient-provider communication. Curr Diab Rep. Dec. 2013;13(6):900-8. [pmid: 24014075].
141 Berg SK, Hertz PG. Outpatient nursing clinic for congenital heart disease patients: Copenhagen Transition Program. J Cardiovasc Nurs. Nov-Dec. 2007;22(6):488-92. [pmid: 18090190].
142 Stinson J, Kohut SA, Spiegel L, et al. A systematic review of transition readiness and transfer satisfaction measures for adolescents with chronic illness. Int J Adolesc Med Health. Jul. 2013;6:1-16. [pmid: 23828488].
143 Woodward JF, Swigonski NL, Ciccarelli MR. Assessing the health, functional characteristics, and health needs of youth attending a noncategorical transition support program. J Adolesc Health. Sep. 2012;51(3):272-8. [pmid: 22921138].
144 Gilliam PP, Ellen JM, Leonard L, et al. Transition of adolescents with HIV to adult care: characteristics and current practices of the adolescent trials network for HIV/AIDS interventions. J Assoc Nurses AIDS Care. Jul-Aug. 2011;22(4):283-94. [pmid: 20541443].
145 Paone MC, Wigle M, Saewyc E. The ON TRAC model for transitional care of adolescents. Prog Transplant. Dec. 2006;16(4):291-302. [pmid: 17183935].
146 Hait E, Arnold JH, Fishman LN. Educate, communicate, anticipate-practical recommendations for transitioning adolescents with IBD to adult health care. Inflamm Bowel Dis. Jan. 2006;12(1):70-3. [pmid: 16374262].
147 Wolfstadt J, Kaufman A, Levitin J, et al. The use and usefulness of My Health Passport: An online tool for the creation of a portable health summary. Int J Child Adolesc Health. 2012-09-10. 2010;3(4):499-506.
148 Chaudhry SR, Keaton M, Nasr SZ. Evaluation of a cystic fibrosis transition program from pediatric to adult care. Pediatr Pulmonol. Jul. 2013;48(7):658-65. [pmid: 22888094].
149 Gleeson H, Davis J, Jones J, et al. The challenge of delivering endocrine care and successful transition to adult services in adolescents with congenital adrenal hyperplasia: experience in a single centre over 18 years. Clin Endocrinol (Oxf). Jan. 2013;78(1):23-8. [pmid: 23009615].
150 Vanelli M, Caronna S, Adinolfi B, et al. Effectiveness of an uninterrupted procedure to transfer adolescents with Type 1 diabetes from the Paediatric to the Adult Clinic held in the same hospital: eight-year experience with the Parma protocol. Diabetes Nutr Metab. Oct. 2004;17(5):304-8. [pmid: 16295053].
151 Cerns S, McCracken C, Rich C. Optimizing adolescent transition to adult care for sickle cell disease. Medsurg Nurs. Jul-Aug. 2013;22(4):255-7. [pmid: 24147324].
152 Rapley P, Davidson PM. Enough of the problem: a review of time for health care transition solutions for young adults with a chronic illness. J Clin Nurs. Feb. 2010;19(3-4):313-23. [pmid: 20500270].
153 Harris KM, Gordon-Larsen P, Chantala K, et al. Longitudinal trends in race/ethnic disparities in leading health indicators from adolescence to young adulthood. Arch Pediatr Adolesc Med. Jan. 2006;160(1):74-81. [pmid: 16389215].
154 Van Walleghem N, MacDonald CA, Dean HJ. Transition of care for young adults with type 1 and 2 diabetes. Pediatr Ann. May. 2012;41(5):e16-20. [pmid: 22587508].
155 Van Cleave J, Leslie LK. Approaching ADHD as a chronic condition: implications for long-term adherence. Pediatr Ann. Jan. 2008;37(1):19-26. [pmid: 18240850].
156 de Beaufort C, Jarosz-Chobot P, Frank M, et al. Transition from pediatric to adult diabetes care: smooth or slippery?. Pediatr Diabetes. Feb. 2010;11(1):24-7. [pmid: 20015124].
157 Davis M, Geller JL, Hunt B. Within-state availability of transition-to-adulthood services for youths with serious mental health conditions. Psychiatr Serv. Nov. 2006;57(11):1594-9. [pmid: 17085607].
158 Burke R, Spoerri M, Price A, et al. Survey of primary care pediatricians on the transition and transfer of adolescents to adult health care. Clin Pediatr (Phila). May. 2008;47(4):347-54. [pmid: 18180341].
159 Park MJ, Adams SH, Irwin CE Jr. Health care services and the transition to young adulthood: challenges and opportunities. Acad Pediatr. Mar-Apr. 2011;11(2):115-22. [pmid: 21296043].
160 Garvey KC, Wolpert HA, Rhodes ET, et al. Health care transition in patients with type 1 diabetes: young adult experiences and relationship to glycemic control. Diabetes Care. Aug. 2012;35(8):1716-22. [pmid: 22699289].
161 Wojciechowski EA, Hurtig A, Dorn L. A natural history study of adolescents and young adults with sickle cell disease as they transfer to adult care: a need for case management services. J Pediatr Nurs. Feb. 2002;17(1):18-27. [pmid: 11891491].
162 Oswald DP, Gilles DL, Cannady MS, et al. Youth with special health care needs: transition to adult health care services. Matern Child Health J. Dec. 2013;17(10):1744-52. [pmid: 23160763].
163 Parr JR, Jolleff N, Gray L, et al. Twenty years of research shows UK child development team provision still varies widely for children with disability. Child Care Health Dev. Nov. 2013;39(6):903-7. [pmid: 23425219].
164 Holmes-Walker DJ, Llewellyn AC, Farrell K. A transition care programme which improves diabetes control and reduces hospital admission rates in young adults with Type 1 diabetes aged 15-25 years. Diabet Med. Jul. 2007;24(7):764-9. [pmid: 17535294].
165 Lane JT, Ferguson A, Hall J, et al. Glycemic control over 3 years in a young adult clinic for patients with type 1 diabetes. Diabetes Res Clin Pract. Dec. 2007;78(3):385-91. [pmid: 17602780].
166 Gholap N, Pillai M, Virmani S, et al. The Alphabet Strategy and standards of care in young adults with type 1 diabetes. The British Journal of Diabetes & Vascular Disease. July. 1. 2006. 2006;6(4):168-70.
167 Smith PE, Myson V, Gibbon F. A teenager epilepsy clinic: observational study. Eur J Neurol. Jul. 2002;9(4):373-6. [pmid: 12099921].
168 Van Walleghem N, Macdonald CA, Dean HJ. Evaluation of a systems navigator model for transition from pediatric to adult care for young adults with type 1 diabetes. Diabetes Care. Aug. 2008;31(8):1529-30. [pmid: 18458141].
169 Dowshen N, D'Angelo L. Health care transition for youth living with HIV/AIDS. Pediatrics. Oct. 2011;128(4):762-71. [pmid: 21930548].
170 Camfield PR, Gibson PA, Douglass LM. Strategies for transitioning to adult care for youth with Lennox-Gastaut syndrome and related disorders. Epilepsia. Aug. Suppl 5. 2011;52:21-7. [pmid: 21790562].
171 Annunziato RA, Hogan B, Barton C, et al. A translational and systemic approach to transferring liver transplant recipients from pediatric to adult-oriented care settings. Pediatr Transplant. Nov. 2010;14(7):823-9. [pmid: 20609174].
172 Chaturvedi S, Jones CL, Walker RG, et al. The transition of kidney transplant recipients: a work in progress. Pediatr Nephrol. May. 2009;24(5):1055-60. [pmid: 19238453].
173 Cadario F, Prodam F, Bellone S, et al. Transition process of patients with type 1 diabetes (T1DM) from paediatric to the adult health care service: a hospital-based approach. Clin Endocrinol (Oxf). Sep. 2009;71(3):346-50. [pmid: 19178523].
174 Annunziato RA, Baisley MC, Arrato N, et al. Strangers Headed to a Strange Land? A Pilot Study of Using a Transition Coordinator to Improve Transfer from Pediatric to Adult Services. J Pediatr. 2013. Aug. 28. [pmid: 23993138].
175 McDonagh JE, Southwood TR, Shaw KL. The impact of a coordinated transitional care programme on adolescents with juvenile idiopathic arthritis. Rheumatology (Oxford). Jan. 2007;46(1):161-8. [pmid: 16790451].
176 Groark CJ, McCall RB. Implementing Changes in Institutions to Improve Young Children's Development. Infant Ment Health J. Sep. 2011;32(5):509-25. [pmid: 22114364].
177 Musumadi L, Westerdale N, Appleby H. An overview of the effects of sickle cell disease in adolescents. Nursing Standard. 2012;26(26):35-40. [pmid: 22482187].
178 Rearick E. Enhancing success in transition service coordinators: use of transformational leadership. Prof Case Manag. Sep-Oct. 2007;12(5):283-7. [pmid: 17885635].
179 Higgins SS, Tong E. Transitioning adolescents with congenital heart disease into adult health care. Prog Cardiovasc Nurs. Spring. 2003;18(2):93-8. [pmid: 12732802].
180 Andemariam B, Owarish-Gross J, Grady J, et al. Identification of risk factors for an unsuccessful transition from pediatric to adult sickle cell disease care. Pediatr Blood Cancer. 2013. Dec. 18. [pmid: 24347402].
181 Osterkamp EM, Costanzo AJ, Ehrhardt BS, et al. Transition of care for adolescent patients with chronic illness: education for nurses. J Contin Educ Nurs. Jan. 2013;44(1):38-42. [pmid: 23413447].
182 Boudreau ME, Fisher CM. Providing effective medical and case management services to HIV-infected youth preparing to transition to adult care. J Assoc Nurses AIDS Care. Jul-Aug. 2012;23(4):318-28. [pmid: 21820326].
183 Camfield P, Camfield C, Pohlmann-Eden B. Transition from pediatric to adult epilepsy care: a difficult process marked by medical and social crisis. Epilepsy Curr. Jul. 2012;12(Suppl 3):13-21. [pmid: 23476118].
184 Nishikawa BR, Daaleman TP, Nageswaran S. Association of provider scope of practice with successful transition for youth with special health care needs. J Adolesc Health. Feb. 2011;48(2):209-11. [pmid: 21257122].
185 Gilleland J, Amaral S, Mee L, et al. Getting ready to leave: transition readiness in adolescent kidney transplant recipients. J Pediatr Psychol. Jan-Feb. 2012;37(1):85-96. [pmid: 21878430].
186 Meran S, Don K, Shah N, et al. Impact of chronic kidney disease management in primary care. QJM. Jan. 2011;104(1):27-34. [pmid: 20805119].
187 Jameson PL. Adolescent Transition: Challenges and Resources for the Diabetes Team. Diabetes Spectrum. 2011. Winter. 2011;24(1):18-21.
188 Patton SR, Graham JL, Varlotta L, et al. Measuring self-care independence in children with cystic fibrosis: the Self-Care Independence Scale (SCIS). Pediatr Pulmonol. Aug. 2003;36(2):123-30. [pmid: 12833491].
189 McDonagh JE, Southwood TR, Shaw KL. Unmet education and training needs of rheumatology health professionals in adolescent health and transitional care. Rheumatology (Oxford). Jun. 2004;43(6):737-43. [pmid: 14997008].
190 Tong A, Jones J, Speerin R, et al. Consumer perspectives on pediatric rheumatology care and service delivery: a qualitative study. J Clin Rheumatol. Aug. 2013;19(5):234-40. [pmid: 23872547].
191 Lariviere-Bastien D, Bell E, Majnemer A, et al. Perspectives of young adults with cerebral palsy on transitioning from pediatric to adult healthcare systems. Semin Pediatr Neurol. Jun. 2013;20(2):154-9. [pmid: 23948690].
192 Montano CB, Young J. Discontinuity in the transition from pediatric to adult health care for patients with attention-deficit/hyperactivity disorder. Postgrad Med. Sep. 2012;124(5):23-32. [pmid: 23095423].
193 Goudie A, Carle AC. Ohio study shows that insurance coverage is critical for children with special health care needs as they transition to adulthood. Health Aff (Millwood). Dec. 2011;30(12):2382-90. [pmid: 22147867].
194 Peters A, Laffel L. Diabetes care for emerging adults: recommendations for transition from pediatric to adult diabetes care systems: a position statement of the American Diabetes Association, with representation by the American College of Osteopathic Family Physicians, the American Academy of Pediatrics, the American Association of Clinical Endocrinologists, the American Osteopathic Association, the Centers for Disease Control and Prevention, Children with Diabetes, The Endocrine Society, the International Society for Pediatric and Adolescent Diabetes, Juvenile Diabetes Research Foundation International, the National Diabetes Education Program, and the Pediatric Endocrine Society (formerly Lawson Wilkins Pediatric Endocrine Society). Diabetes Care. Nov. 2011;34(11):2477-85. [pmid: 22025785].
195 Packel L, Sood M, Gormley M, et al. A pilot study exploring the role of physical therapists and transition in care of pediatric patients with cystic fibrosis to the adult setting. Cardiopulm Phys Ther J. Mar. 2013;24(1):24-30. [pmid: 23754936].
196 Garvey KC, Markowitz JT, Laffel LM. Transition to adult care for youth with type 1 diabetes. Curr Diab Rep. Oct. 2012;12(5):533-41. [pmid: 22922877].
197 Coleman R, Moore S. Future considerations in the transition of paediatric neurodevelopmental patients to adult services. Australasian Journal of Neuroscience. 2006;18(1):15-20.
198 Kreindler JL, Miller VA. Cystic fibrosis: addressing the transition from pediatric to adult-oriented health care. Patient Prefer Adherence. 2013;7:1221-6. [pmid: 24376344].
199 Fernandes SM, Khairy P, Fishman L, et al. Referral patterns and perceived barriers to adult congenital heart disease care: results of a survey of U.S. pediatric cardiologists. J Am Coll Cardiol. Dec. 11. 2012;60(23):2411-8. [pmid: 23141490].
200 Bitsko MJ, Everhart RS, Rubin BK. The Adolescent with Asthma. Paediatr Respir Rev. 2013. Aug. 21. [pmid: 23972334].
201 Van Lierde A, Menni F, Bedeschi MF, et al. Healthcare transition in patients with rare genetic disorders with and without developmental disability: neurofibromatosis 1 and Williams-Beuren syndrome. Am J Med Genet A. Jul. 2013;161a(7):1666-74. [pmid: 23696535].
202 Vidqvist KL, Malin M, Varjolahti-Lehtinen T, et al. Disease activity of idiopathic juvenile arthritis continues through adolescence despite the use of biologic therapies. Rheumatology (Oxford). Nov. 2013;52(11):1999-2003. [pmid: 23893666].
203 Shemesh E, Annunziato RA, Arnon R, et al. Adherence to medical recommendations and transition to adult services in pediatric transplant recipients. Curr Opin Organ Transplant. Jun. 2010;15(3):288-92. [pmid: 20445451].
204 Woldorf JW. Transitioning adolescents with special healthcare needs: potential barriers and ethical conflicts. J Spec Pediatr Nurs. Jan. 2007;12(1):53-5. [pmid: 17233668].
205 Stewart DA, Law MC, Rosenbaum P, et al. A qualitative study of the transition to adulthood for youth with physical disabilities. Phys Occup Ther Pediatr. 2001;21(4):3-21. [pmid: 12043171].
206 Chamberlain MA, Kent RM. The needs of young people with disabilities in transition from paediatric to adult services. Eura Medicophys. Jun. 2005;41(2):111-23. [pmid: 16200026].
207 Harden PN, Walsh G, Bandler N, et al. Bridging the gap: an integrated paediatric to adult clinical service for young adults with kidney failure. BMJ. 2012;344:e3718. [pmid: 22661725].
208 Bundock H, Fidler S, Clarke S, et al. Crossing the divide: transition care services for young people with HIV-their views. AIDS Patient Care STDS. Aug. 2011;25(8):465-73. [pmid: 21745141].
209 Jurasek L, Ray L, Quigley D. Development and implementation of an adolescent epilepsy transition clinic. J Neurosci Nurs. Aug. 2010;42(4):181-9. [pmid: 20804112].
210 Van Walleghem N, MacDonald CA, Dean HJ. Building connections for young adults with type 1 diabetes mellitus in Manitoba: feasibility and acceptability of a transition initiative. Chronic Dis Can. 2006;27(3):130-4. [pmid: 17306065].
211 Bent N, Tennant A, Swift T, et al. Team approach versus ad hoc health services for young people with physical disabilities: a retrospective cohort study. Lancet. Oct. 26. 2002;360(9342):1280-6. [pmid: 12414202].
212 Hankins JS, Osarogiagbon R, Adams-Graves P, et al. A transition pilot program for adolescents with sickle cell disease. J Pediatr Health Care. Nov-Dec. 2012;26(6):e45-9. [pmid: 22819193].
213 Vidal M, Jansa M, Anguita C, et al. Impact of a special therapeutic education programme in patients transferred from a paediatric to an adult diabetes unit. European Diabetes Nursing. 2004;1(1):23-7.
214 Betz CL, Smith K, Macias K. Testing the transition preparation training program: A randomized controlled trial. Int J Child Adolesc Health. 2010;3(4):595-607. [pmid: 22229060].
215 Greveson K, Morgan N, Furman M, et al. Attitudes and experiences of adolescents in an innovative IBD transition service. Gastrointestinal Nursing. 2011;9(1):35-40.
216 Shaw KL, Southwood TR, McDonagh JE. Young people's satisfaction of transitional care in adolescent rheumatology in the UK. Child Care Health Dev. Jul. 2007;33(4):368-79. [pmid: 17584391].
217 Miller VA, Harris D. Measuring children's decision-making involvement regarding chronic illness management. J Pediatr Psychol. Apr. 2012;37(3):292-306. [pmid: 22138318].
218 Koike S, Takano Y, Iwashiro N, et al. A multimodal approach to investigate biomarkers for psychosis in a clinical setting: the integrative neuroimaging studies in schizophrenia targeting for early intervention and prevention (IN-STEP) project. Schizophr Res. Jan. 2013;143(1):116-24. [pmid: 23219075].
219 Amiel SA, Sherwin RS, Simonson DC, et al. Impaired insulin action in puberty. A contributing factor to poor glycemic control in adolescents with diabetes. N Engl J Med. Jul. 24. 1986;315(4):215-9. [pmid: 3523245].
220 Urakami T, Suzuki J, Yoshida A, et al. Association between Sex, Age, Insulin Regimens and Glycemic Control in Children and Adolescents with Type 1 Diabetes. Clin Pediatr Endocrinol. Jan. 2010;19(1):1-6. [pmid: 23926371].
221 Lyons SK, Becker DJ, Helgeson VS. Transfer from pediatric to adult health care: effects on diabetes outcomes. Pediatr Diabetes. 2013. Dec. 18. [pmid: 24350767].
222 Davidson EJ, Silva TJ, Sofis LA, et al. The doctor's dilemma: challenges for the primary care physician caring for the child with special health care needs. Ambul Pediatr. May-Jun. 2002;2(3):218-23. [pmid: 12014983].
223 DeBaun MR, Telfair J. Transition and sickle cell disease. Pediatrics. Nov. 2012;130(5):926-35. [pmid: 23027174].
224 LaRosa C, Glah C, Baluarte HJ, et al. Solid-organ transplantation in childhood: transitioning to adult health care. Pediatrics. Apr. 2011;127(4):742-53. [pmid: 21382946].
225 Sawyer SM, Macnee S. Transition to adult health care for adolescents with spina bifida: research issues. Dev Disabil Res Rev. 2010;16(1):60-5. [pmid: 20419772].
226 Kaufman H, Horricks L, Kaufman M. Ethical considerations in transition. Int J Adolesc Med Health. Oct-Dec. 2010;22(4):453-9. [pmid: 21404876].
227 Kanter J, Kruse-Jarres R. Management of sickle cell disease from childhood through adulthood. Blood Rev. Nov. 2013;27(6):279-87. [pmid: 24094945].
228 Bailey S, O'Connell B, Pearce J. The transition from paediatric to adult health care services for young adults with a disability: an ethical perspective. Aust Health Rev. 2003;26(1):64-9. [pmid: 15485375].
229 Persson A, Newman C. When HIV-positive children grow up: a critical analysis of the transition literature in developed countries. Qual Health Res. May. 2012;22(5):656-67. [pmid: 22218268].
230 Van Deyk K, Moons P, Gewillig M, et al. Educational and behavioral issues in transitioning from pediatric cardiology to adult-centered health care. Nurs Clin North Am. Dec. 2004;39(4):755-68. [pmid: 15561158].
231 Watson R, Parr JR, Joyce C, et al. Models of transitional care for young people with complex health needs: a scoping review. Child Care Health Dev. Nov. 2011;37(6):780-91. [pmid: 22007977].
232 Fletcher-Johnston M, Marshall SK, Straatman L. Healthcare transitions for adolescents with chronic life-threatening conditions using a Delphi method to identify research priorities for clinicians and academics in Canada. Child Care Health Dev. Nov. 2011;37(6):875-82. [pmid: 22007988].
233 McLaughlin S, Bowering N, Crosby B, et al. Health care transition for adolescents with special health care needs: a report on the development and use of a clinical transition service. R I Med J (2013). 2013;96(4):25-7. [pmid: 23641448].
234 McDonagh JE, Kelly DA. The challenges and opportunities for transitional care research. Pediatr Transplant. Sep. 1. 2010;14(6):688-700. [pmid: 20557475].
235 Beresford B. On the road to nowhere? Young disabled people and transition. Child Care Health Dev. Nov. 2004;30(6):581-7. [pmid: 15527469].
236 Grol R, Baker R, Moss F. Quality improvement research: understanding the science of change in health care. Qual Saf Health Care. Jun. 2002;11(2):110-1. [pmid: 12448794].
237 Grol R, Baker R, Moss F. Quality improvement research: understanding the science of change in healthcare. London. BMJ. 2004.
238 Weitzman ER, Kaci L, Quinn M, et al. Helping high-risk youth move through high-risk periods: personally controlled health records for improving social and health care transitions. J Diabetes Sci Technol. Jan. 2011;5(1):47-54. [pmid: 21303624].
239 Huang JS, Terrones L, Tompane T, et al. Preparing Adolescents With Chronic Disease for Transition to Adult Care: A Technology Program. Pediatrics. 2014. May. 19. [pmid: 24843066].