# Next Steps

Research needs are wide-ranging, including both substantive and methodologic concerns. At this point in time, the field lacks even a consistent and accepted way of measuring transition success, and it will be essential to establish consistent goals in order to build an adequate body of literature to affect practice.

One example of current efforts is The Health Care Transition Research Consortium, a volunteer organization of adolescent/young adult patients and health providers/researchers whose mission is to advance an evidence-based research agenda on health care transition. Stated goals include validated assessment tools to assess transition readiness, development and evaluation of interventions to improve transition process and disease self-management, and development of practice-based health care transition research networks (https://sites.google.com/site/healthcaretransition).

An important consideration going forward is recognizing that while the health care system as a whole should more uniformly address transition needs for children with special health care needs, the specific implementations will reflect the substantial heterogeneity of this population. For example, transition care for chronic conditions like diabetes may warrant a different approach than care provided for more heterogeneous and complex conditions, particularly those that include a behavioral or intellectual component. Care for some patients may be appropriately provided in primary care at the community level, while for others, it may be available only in highly specialized regional or academic centers. This heterogeneity and implications for approaches to transition care could form an important basis for research, including identifying predictors of successful transition as well as assessing the appropriateness of common elements of transition care for different conditions and identifying which elements should be different.

The impact of aging out of both Medicaid and Title V services for youth receiving them as children warrants consideration in development of transition plans, both in terms of educating youth and their families and in developing realistic plans for accessing care. As noted in the report, the concept of transition care in pediatrics is closely aligned with the medical home, and in fact, the “Got Transition” approach is built on the medical home concept. With implementation of the Affordable Care Act and increasing emphasis on coordinated care in accountable care organizations, there may be a natural place for transition services to be a part of new approaches to healthcare currently being piloted and implemented.

As noted in our brief, although Got Transition38 principles are described by experts as the ideal basis for transition care, intervention studies are reported in such a way that we were unable to track back their interventions to these principles. If investigators would at minimum describe their interventions with the Got Transition38 rubric—or another agreed upon rubric—then synthesizing the literature as it evolves would be more straightforward and enhance applicability.

Research on the costs and resources needed to provide good care will improve the likelihood of diffusion and may provide a basis for understanding reimbursement challenges. The broad availability of tools and materials to support providers and teams have the potential to reduce costs and increase provision of care.