# Methods

We used discussions with Key Informants, a search of the gray literature, and a search of the published literature to collect relevant data and descriptions.

## Data Collection

### Discussions With Key Informants

We engaged Key Informants to offer insight into the clinical context of transition care, and suggest issues of greatest importance to clinicians, patients, researchers, and payers. We searched the Web sites of relevant professional organizations and research and policy groups to identify stakeholders whose work or interests indicate a high likelihood of interest and expertise in the topic.

In consultation with the investigative team and the Agency for Healthcare Research and Quality (AHRQ), we assembled a list of individuals representing a clinical, policy, research, or advocate perspective for transition care. Four of 18 invited individuals agreed to participate. Following approval by AHRQ of the completed Disclosure of Interest forms for proposed Key Informants, we conducted discussions with four Key Informants, representing clinicians in practice as well as in policy roles in addition to accomplished researchers.

We conducted one group discussion by telephone with Key Informants. We invited the Key Informants to share their experiences and make suggestions to the proposed Technical Brief. Before the call, we developed a list of general guiding questions for call participants and provided the call participants with a copy of the proposed guiding questions. We asked Key Informants to provide perspective on the CSHCN populations and clinical subgroups of interest, interventions for comparison, relevant outcomes, timing for interventions and outcomes, and other information that would make this report most useful to decision makers. We recorded and transcribed the call discussion and generated a summary that we distributed to call participants.

We used the input from the Key Informants to confirm our initial findings and verify the feasibility of the scope established by the team for the Technical Brief. In particular, we asked Key Informants about issues related to definitions, clinical areas, population, implementation, resources, and future research needs.

### Published Literature Search

We used a combination of controlled vocabulary terms and keywords to search the published literature for studies that specifically evaluated transition programs. The definition of CSHCN is broad and may encompass many diagnoses and substantial heterogeneity in medical complexity. We used a terms for specific chronic diseases (e.g., asthma) and disabilities (e.g., blindness), as well as broad terms (e.g., congenital defects) and descriptors of youth with special health needs and transition care (e.g., continuity of patient care). We searched the literature base from 2000 on. We reviewed the reference lists of retrieved publications for other potentially relevant publications missed by the search strategies. We present the literature search details in Appendix A.

To identify newly published relevant literature, we updated the literature search during peer review and the posting period for public comments. We incorporated the results from the literature update into the Technical Brief.

We developed forms (Appendix B) for screening and data collection from the published literature. We recorded the study design and study populations from relevant sources. We focused on transition care from pediatric to adult services for individuals with chronic conditions. We did not limit by clinical condition, as a goal of this review was to identify common characteristics of effective transition support across clinical conditions. We limited by type of care, excluding studies of transition care in the context of palliative or hospice care.

We further limited the literature search results for Guiding Question 3 to original research studies. Table 1 summarizes the inclusion and exclusion criteria for the evaluation studies that were included in Guiding Question 3. We scanned the text of all included publications for information on barriers, training needs, variation in practice, and the potential impact of transition care on economic and policy decisions.

Table 1 Inclusion and exclusion criteria for evaluation studies

Category | Criteria
Study population | Children with special health care needs
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs] Randomized controlled trials(including wait-list control), cohorts with comparison, pre-post cohort without comparison, stepped wedge designs, case-control, case series, and case reports [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results.; - Studies must address the following for transitions in care:; ○ Transitions of care from pediatric to adult services.; ○ Children with special health needs as defined by the American Academy of Pediatrics.; ○ A special health need that arises from a chronic physical, developmental, or intellectual condition or disability.

### Gray Literature Search

We augmented the searches we conducted in bibliographic databases by searching for gray literature. Examples of sources of gray literature include the Internet, government Web sites, clinical trial databases, trade publications, and meeting abstracts. We crosschecked the findings from the gray literature searches against the literature retrieval for publications that we may have missed in the literature searches.

We searched Web sites of relevant professional associations and patient advocate groups for information on transition care programs and strategies for special health care needs. We performed searches of public health department Web sites for each state for online descriptions or links to existing transition care programs or models. We accessed NIH RePORTER, HSRProj, and ClinicalTrials.gov to identify ongoing research. Appendix C presents details of our findings from the gray literature.

## Data Organization and Presentation

We summarize information extracted from the published and gray literature in the results and discussion of this report. We organize the transition care components into categories and describe commonalities among existing transition care models or programs, as well as approaches that warrant further evaluation (Guiding Question 1). We identify resources for and barriers to adoption and implementation of transition care (Guiding Question 2). We present information on current practice and research in summary tables and text (Guiding Question 3). We highlight the implications of existing transition care practice and the need for future research in Guiding Question 4.

We used gray literature sources to locate innovative transition care models and programs and present this information in tables in Appendix C. We catalogued information on transition care services from individual States and health care systems as it was available (Appendix C). We documented reasons for exclusion of records that were promoted for full text review (Appendix D).

## Peer Review

A draft of this Technical Brief was posted to the AHRQ Web site for 4 weeks for public comments. During this time, the Scientific Resource Center distributed the draft report to individuals who agreed to serve as peer reviewers. The Scientific Resource Center collected the feedback from peer reviewers and forwarded the compiled comments to report authors. We reviewed the comments and made appropriate changes to the final report.

We documented the report revisions and provided a summary of responses to the individual comments received from public and peer reviewers in a disposition of comments table. The disposition of comments table will be available on the AHRQ Web site after publication of the final Technical Brief Report.