# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rachel Annunziato, Ph.D.
  Fordham University
  Bronx, NY
- Michael S. Barr, M.D., M.B.A., FACP
  Division of Medical Practice
  American College of Physicians
  Washington, D.C.
- Cecily L. Betz, Ph.D., R.N., FAAN
  USC UCEDD at Children's Hospital
  Los Angeles, CA
- William Carl Cooley, M.D.
  Crotched Mountain Rehabilitation Center
  Greenfield, NH
- Charles J. Homer, M.D., M.P.H.
  Chief Executive Officer and President,
  National Initiative for Children's Healthcare Quality
  Boston, MA
- Marie Mann, M.D., M.P.H.
  Maternal and Child Health Bureau
  Rockville, MD
- Elise McMillan, J.D.
  Vanderbilt Kennedy Center for Excellence in Developmental Disabilities
  Nashville, TN
- Megumi J. Okumura M.D., M.A.S.
  Division of General Pediatrics
  Division of General Internal Medicine
  University of California San Francisco
  San Francisco, CA
- Melissa Parisi, Ph.D., M.D.
  Intellectual and Developmental Disabilities Branch
  Eunice Kennedy Shriver National Institute of Child Health and Human Development
  National Institutes of Health
  Bethesda, MD
- Cynthia Peacock, M.D., FAAP, FACP
  Baylor Transition Medicine Clinic
  Houston, TX
- John Reiss, Ph.D., M.A.
  Institute for Child Health Policy
  University of Florida
  Gainesville, FL
- Lisa A. Schwartz, Ph.D.
  The Children's Hospital of Philadelphia
  Perelman School of Medicine, University of Pennsylvania
  Philadelphia, PA