# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the Evidence-based Practice Center work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Michael S. Barr, M.D., M.B.A., FACP
  Division of Medical Practice
  American College of Physicians
  Washington, D.C.
- Charles J. Homer, M.D., M.P.H.
  Chief Executive Officer and President
  National Initiative for Children's Healthcare
  Quality
  Boston, MA
- Marie Mann, M.D., M.P.H.
  Maternal and Child Health Bureau
  Rockville, MD
- Elise McMillan, J.D.
  Vanderbilt Kennedy Center for Excellence in Developmental Disabilities
  Nashville, TN
- Cynthia Peacock, M.D., FAAP, FACP
  Baylor Transition Medicine Clinic
  Houston, TX