# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Rebecca Jerome, Ms. Natalie A. Henninger, Ms. Tanya Surawicz, Ms. Sanura Latham, and Ms. Jessica Kimber.