# Findings

In this section, we summarize information from the published and gray literature sources to address Guiding Questions 1–4. Much of the discussion with Key Informants was consistent with the salient topics that emerged from the body of literature, focusing primarily upon the need for, implications of, and barriers to the adoption of seamless, effective, and comprehensive transition care for children and youth with special health care needs (CSHCN).

We summarize the literature on the purpose and current approaches for transition care using the framework of Got Transition38 as an organizational structure (Guiding Question 1). This is not an endorsement of the framework, but as the most well-known and publicly available approach, it provides a logical and accessible organizational structure. We then provide a discussion of resources, barriers and other contextual issues important to the implementation and adoption of transition strategies (Guiding Question 2). The results presented here are a combination of a summary of the literature and our Key Informant conversations. We present the state of the current research, identifying the sources and findings from evaluation studies of transition approaches in Guiding Question 3. We present implications and areas for future research in Guiding Question 4.

## Guiding Question 1 Description of Interventions for Transition Care

a. What are the goals of transition care and what are the theoretical advantages and disadvantages?
b. What are the common components of transition care interventions or processes used in clinical practice for children/adolescents with special health care needs?
c. How do currently used approaches to transitioning health care address the complexity of health issues including comorbidities and the presence of both physical and intellectual/developmental disabilities?

### Goals of Transition Care (Guiding Question1a)

The provision of high quality transition care for youth with special health care needs should optimize the patient's quality of life and ensure continued access to and appropriate use of clinical care.34,36,39-46 More specifically, the American Academy of Pediatrics (AAP) suggests that good transition care follow the principles of the medical home. Transition care should be coordinated, comprehensive, individualized, culturally competent, and patient-centered.27,40,43,47-57 The AAP also recommends that the transition program promote skills in communication, decision-making, assertiveness, and self-care to enhance a sense of control and independence of health care for youth.40,43,55

Several professional organizations including the American Academy of Family Physicians (AAFP), the American College of Physicians (ACP), the Society for Adolescent Health and Medicine, the Canadian Pediatric Society, and the National Association of Pediatric Nurse Practitioners and Nurses also endorse these functional goals.50,58-60 Key Informants in this process stated that transition care should be based upon these principles, but that specific programs should be designed to match the specific needs of the patient population and the health care system.

Increased prevalence of chronic and disabling disease paired with improvements in early diagnosis and treatment of those conditions have led to increasing numbers of children and youth with special health care needs living into adulthood.27,34,61-65 Based on the most recent estimate from the AAP in 2002, more than 90 percent of CSHCN now survive into adulthood, and approximately 750,000 CSHCN make the transition to adulthood annually in the United States.1,34,51,58,60,66-70

Current practice involves a range from simple transfer of care from pediatric to adult settings that occurs at a set time-point to a well-planned and coordinated transition of care that occurs over time and encompasses elements both before and after the anticipated transfer of care.71-73 When transition involves only an abrupt care transfer, patients may be put at risk of getting “lost in the system” or experiencing decreased access to care, both of which may be associated with poorer long-term health outcomes, impaired function, and high-cost emergency care.49,50,65,67,74,75 One of the goals of transition care is therefore to prevent these adverse outcomes.

#### Advantages

Proposed benefits of purposeful transition care are that it provides youth with ongoing access to primary care and subspecialist care, promotes competence in disease management, fosters independence, social, and emotional development through teaching self-advocacy and communication skills, and allows for a sense of security for support of long-term health care planning and life goals. Self-care behaviors learned from well-executed health transition care during adolescence may also be useful during other periods of transition, such as changes in residence, insurance, and personal preference.76

Direct benefits of transition care to the patient include improved disease control, decreased hospital admissions, better quality of life, and increased patient satisfaction,77-79 but further research is needed to determine how best to implement transition care and if such efforts translate into long-term improvements in overall health outcomes.75,80 Transfer of care to an adult provider, as a component of transition care, provides the benefit of access to targeted care for issues related to adulthood and aging, which may be better handled by adult providers. Adult providers are also better suited to address issues such as pregnancy and comorbidities associated with adult lifestyle and aging.81,82

Finally, post-transition perspective surveys suggest that although CSHCN appreciate the increased autonomy received in adult clinics, they report that a transition program (as opposed to a transfer of care) would be beneficial.83,84

#### Disadvantages

An inherent disadvantage of transfer of care includes a change in the health care provider and a move away from a familiar pediatric setting. As illustrated in a study published in 2011 that assessed the transfer experiences and medical outcomes of a cohort of individuals with HIV acquired in childhood, the transition to adult care was more difficult than expected, and youth reported feelings of abandonment and sadness with the loss of patient-provider relationship after transfer to adult health care. Almost one half of the participants who transferred to adult care (19/42) reported problems with medication adherence. This study also reported that CD4 counts trended downward, clinically indicating worsening disease status, from pre- to post-transfer.85 Other studies report young adults with sickle cell disease transferring from pediatric clinics experiencing increased episodes of pain and greater mortality,86-88 premature deaths after transfer for young people with congenital heart disease,63 and high rates of rejection and allograft loss among youth with transplants immediately following transfer.42,63,81,89,90

Some subgroups of patients may be at increased risk for poorer outcomes. For example, a retrospective review of administrative and survey data of young adults with diabetes found that individuals in the lowest income group were less likely to attend an eye care visit in the two years after transition to adult diabetes care than were individuals from other income groups.23 Patients transferred to a new health care team who did not change physicians were less likely to be hospitalized after the transfer than were patients who changed physicians, regardless of whether or not they also transferred to a new health care team.23

None of these disadvantages is related to good transition planning; rather these are disadvantages of moving from a pediatric health care system to an adult health care system in circumstances where there are inadequate supports. Actual disadvantages of well-executed transition care have not been formally studied. At the system level, potential disadvantages of true transition care may include high costs of providing care and lack of reimbursement for these services, costs of system changes during development and implementation phases for transition programs, and loss of revenue for children's hospitals (i.e. movement of congenital heart disease cases to adult hospitals). However, studies comparing cost-effectiveness of transition care for children with special health care needs and cost of unsuccessful transition are lacking.

### Components of Transition Care (Guiding Question 1b)

Although there is common endorsement in the literature for the need for transition planning for CSHCN, a range of approaches to improving the process and structure of transition care has been proposed, and no gold standard for transition care exists.51,64,83,90 The most common practice models are: a primary care model where the general practitioner provides ongoing medical care and implements and/or uses transition related services and supports, a transition coordination model where a consultative, multidisciplinary team facilitates the transition, and an adolescent-focused model where youth transition to adult care through an adolescent specialist service.45,70,91 Disease-specific or subspecialty-based transition programs also exist and may use any one of the models described above in a disease-specific way.54,64,70,75,79,92-95

It is worth noting that although patients cared for by family practitioners may theoretically have the same primary care physician in childhood and adulthood, these patients may still benefit from a process to help them assume increasing responsibility for their own care as they age and may still need to transfer some of their care from pediatric to adult specialists. There are no empirical data in the literature to guide decisions regarding whether primary care transition and subspecialty care transitions should occur simultaneously or in a sequential fashion.

Key informants noted that varying approaches to transition care may be warranted and appropriate given the heterogeneity of CSHCN, both by diagnosis and by level of medical complexity. For example, discussion of infection control policies will be an important aspect of transition programs for patients with cystic fibrosis,96 while transition programs for youth with HIV will likely incorporate strategies to address the stigma surrounding this diagnosis.57,77,83 The format that is adopted also depends on the facilities and resources available.39,43,53,56,58,62,64,82,97-99 Likewise, the Society for Adolescent Medicine recommends that one of the basic principles for successful transition is “to have individualized and flexible enough programs to meet the needs of young people and their families.”68,75

Despite documented variation and a focus on flexibility in transition approaches, there is a core set of common components of quality transition care. Experts, including this project's Key Informants, point to the Got Transition Six Core Elements of Health Care Transition37 as a useful framework that is widely accessible and flexible. Got Transition is the name of The National Alliance to Advance Adolescent Health initiative supported by the U.S. Maternal and Child Bureau/Health Resources and Services Administration. These efforts led four practice-based Breakthrough Series-style Learning Collaboratives, adapting quality improvement methodology used by the National Initiative for Children's Healthcare Quality (NICHQ) and pioneered by the Institute for Healthcare Improvement (IHI) to generate and test its suggested transition framework.

The core elements defined by Got Transition38 mirror the algorithm for best practices in the clinical report titled “Supporting the Health Care Transition From Adolescence to Adulthood in the Medical Home” that was jointly published by the AAP, AAFP, and ACP.36,37 These core elements, or components, of health care transition are transition policy, transitioning youth registry, transition preparation, transition planning, transition and transfer of care, and transition completion and apply to both pediatric and adult health care settings.38 These components underscore the key concept that transition care is a process that involves actionable steps by both pediatric and adult provider, not a single event or passive process.

Each of these components can be augmented by the use of specific tools to address issues including comorbidities, the presence of both physical and intellectual disabilities, and confounding psychosocial circumstances. Different tools may be used for different groups of patients or different clinical settings. Incorporation and implementation of different tools also may vary based on available resources and support services. Most published transition programs incorporate multiple components and tools, making assessment of individual components difficult.78,100

We have organized the review of the literature addressing transition care components (Guiding Question 1b) around the Got Transition38 algorithm based on advice from this project's Key Informants. However, given the recognized need for further evidence-based recommendations in this field, we do not formally endorse the program. Rather, as noted elsewhere in this report, we use it as an organizing tool; we recognize that some users of this report may prefer other approaches to organizing the literature.

#### Transition Policy

An explicit transition policy describes the practice's approach to health care transition, outlines goals of the program, and clarifies the roles and responsibilities of the youth, family, and health care team.36,43,52,75,97,101-103 Development of policies may involve both pediatric and adult transition teams.62,92,104,105

The transition policy typically includes a timeline with a suggested age for beginning the transition process and tentative deadline for ultimate transfer of care.40,97 It is frequently recommended in the published literature that transition care start early, perhaps as young as 10 to 12 years of age, to allow for an adequate period of preparation,43,52,53,60,62,66,74,83,97,99,105-111 and some advocate for beginning the process at time of diagnosis.112,113 There is little empirical evidence, however, about optimal age at which to begin the process.

Timing of transfer takes into account the youth's cognitive development, physical abilities, and environment, which includes socioeconomic characteristics and psychosocial resources including family or peer support.48,51,57,99,109,112,114-116 In particular, it is typically recommended that transfer of care not take place during a period of health crisis, especially if the support system is unstable.99,113,115-118

Nonetheless, having a target age of transfer could be useful to catalyze transition activities to plan and prepare for the ultimate transfer of care. Age 18 years is most commonly considered an acceptable age for transfer,62,65,92,106,112,114,119 and this is the age at which parents loose access to their child's medical records. However, the range of suggested age of transfer is from 12 years100 to 25 years.97,120 The wide range of suggested transfer age in the literature may underscore that timing of transfer of care should be individualized.100,120,121

Other suggestions for introducing anticipated transition that we identified in our search were transition alert letters, videos, and pamphlets or books.61,122 Pamphlets, in particular, theoretically offer an accessible, portable, convenient, and cost-effective means for information distribution.122

#### Transition Registry

Some medical practices maintain transition registries to help identify patients with special health care needs at the appropriate chronologic age for transition and enable a system for monitoring which steps of the transition process still need to be completed.36,97 Use of electronic health record systems can facilitate development and organization of such registries.123 Minimal information is available at this time regarding the utility of and implementation strategies for transition registries as a component of a transition program. Nonetheless, the use of a registry to track the status of patients with special health care needs and also to stratify them in terms of complexity is endorsed as an important distinction of a medical home.36

#### Transition Preparation

Youth, their families and their providers all need to be prepared to initiate and complete a transition process. Key Informants reported that providers may not have access to adequate training to manage the challenges associated with transition and that adult providers may be unprepared to care for CSHCN who transfer to adult care, and this opinion is echoed the published literature. Thus, transition care involves active preparation on the part of providers, transitioning youth, and their families. Educational needs exist for both the clinical team and the patients and their families in preparation for transition.34,40,66,111,117

First, some health care providers may need additional education on transition care topics and professional training in caring for adolescent patients.36,66,103,124 Team members may need to be supported with continuing medical education programs that are tailored for their specific functional needs as a member of the transition team.87 One specific educational resource for health care providers is the Transition-Oriented Health Supervision (TOHS), based upon the American Academy of Pediatrics Bright Futures developmental approach to health supervision, which helps guide clinical encounters to prepare CSHCN, and their families, for the necessary move from pediatric to adult health care.19 The AAP is also developing Maintenance of Certification modules addressing transition planning.123

Second, youth and family report a need for education about the differences between pediatric and adult care and may receive ongoing anticipatory guidance regarding what to expect from adult specialty care36,66,83,118 as well as instruction for navigating the system of entitlements, such as Medicaid and Supplemental Security Income.55,83 Youth and their parents also report the need for disease-specific education during this time.125

Transition should include a formal transition curriculum to address medical and non-medical issues including disease-specific topics, skills training in communication, decisionmaking, creative problem solving, assertiveness, self-care, self-determination, and self-advocacy.43,51-53,57,66,71,75,78,103,116 Incorporation of online materials and text messaging can be a useful tool to promote health management skills in adolescents.126

Transition preparation also is recommended to include support for youth and their family.43,51,55,60,82,98,101,111,117 Both family and peer support groups or mentoring programs have been proposed as forms of support and education during the transition process.36,54,77,97,99,108-110,112,126,127 The Adolescent Leadership Council128 is an example of a group-mentoring program that brings together high school students with chronic illness and college student mentors with chronic illness. Participants have reported that they learned to better care for their illness and gained skills talking about their illness, and investigators reported a small increase in transition readiness scores for participants in the program, although successful transitioning has not been evaluated.128

Another example is the Good2Go Transition Program129 which used psycho-educational transition groups to discuss issues of self-advocacy, independent behaviors, health lifestyle issues, and health care access strategies. These groups were also available to support parents in growing independence of their adolescent.50

Mentoring via email or internet chat rooms has also been proposed but not evaluated.54,130 Summer camps are another option that could provide opportunities to increase social networks and promote development of self-management skills.131

Transition care programs typically attempt to be family-centered and engage the family in the process by recognizing that the family's role in care of the young adult is not necessarily diminishing, but changing to a more consultative role for health care needs.43,54,83,99,107,132

Some studies report that continued involvement of parents in youth's lives has a protective effect on better health outcomes.125,133 Thus, transition planning with parents may be a beneficial aspect of transition preparation for the youth.75,134 Examples of opportunities for family engagement include concurrent visits for parents, specific focus on fathers, and modeling of healthy lifestyles.42,44,78,101,135 Printed materials to educate and coach parents about their evolving role, particularly as it pertains to communication and co-management, are available through Family Voices.136

#### Transition Planning

##### Individualized Transition Plan

There is a marked emphasis in the literature supporting a formal, individualized transition plan documented in the medical record.1,34,36,42,43,52,57,65,97,99,101,112,137,138 Careful documentation in the patient chart of intent to transfer to an adult health care provider and details regarding transition conversations among patients and providers may predict successful transfer of care.76,107 The transition plan generally includes goals for achieving self-care, health care decision-making, and self-advocacy and outlines specific actions required to achieve these goals.60,67 The transition plan also documents the expectations for the adolescent's knowledge and understanding about his or her condition57,66 and addresses strategies for securing health insurance.34 Key informants provided information on the degree to which developing such a plan is time intensive, but essential for ensuring that the process goes well.

In theory, collaborative development of a transition plan may enhance communication between the patient and the health care provider and helps parents learn to consider their child's future capacity in multiple domains such as education, employment, and independent living, and it helps adolescents learn that they will be expected to take gradual increased responsibility for their health care.76,139 Enhancing patient-provider communication has been cited as a means for smoothing the transition to adult care.140 Multiple approaches may be used to facilitate communication; for example holding visits in a consultation room without examination equipment and the provider-patient dialogue taking place sitting around a table rather than behind a desk.141

##### Assessing Readiness

Most transition programs suggest that assessment of transition readiness can guide individualized interventions that promote appropriate patient education and skill development.36,49,66,97,98,108,122 Readiness assessment tools also offer the added advantage of measuring overlapping constructs or assessing the continuum of transition preparedness as opposed to the simple “yes/no” questions on checklists.49,67,98 Readiness assessment tools can also be used to measure clinical outcomes of developing transition programs.142 A systematic review completed by Stinson and colleagues in September 2012 identified seven transition readiness measures, but found that none of these tools had been appropriately psychometrically tested to establish validity and reliability.142

In the absence of rigorously tested transition readiness tools, use of behavior theories, such as the transtheoretical model and stages of change, to assess patient readiness has been suggested. The five stages of change in the transtheoretical model are precontemplation, contemplation, preparation, action, and maintenance and can describe transition from a patient who has not yet considered transition to the adult health care system through a patient that fully accepts responsibility for his/her health.102

##### Legal Considerations

Some youth with special health care needs will not attain independence because of significant developmental or functional disabilities. Discussions about guardianship, health care power of attorney, and other legal issues may need to take place during transition preparation.36,123,143 It is recommended that such youth have a functional competency assessment well before age 18 to determine specific supports needed and arrange for these supports in order to increase self-determination.111

Medical providers providing transition care recognize that parents appointed as legal guardians will remain involved in the youth's care for the remainder of the individual's life.51 Appropriate steps can be taken to ensure these parents continue to have access to their child's medical records even after their child reaches 18 years of age. Parental estate planning to protect Supplemental Security Income eligibility should also be considered during the transition planning period.111 The transition period also provides an opportunity to hold end-of-life and emergency planning discussions collaboratively and without urgency.53,116,143

#### Transfer of Care

The transfer of care from a pediatric to adult provider is just one concrete aspect of the overall transition process. Nonetheless, much of the empirical literature uses successful transfer as a measure of effectiveness.

Checklists, portable medical summaries, and meeting the adult provider before transfer are often recommended as part of the transfer of care process.48,62,63,96,98,99,102,103,109,114,135,144 Table 2 summarizes specific examples of these tools.

Table 2 Tools to aid transition and transfer

Tool | Description | Examples
Checklists | - May be placed in the patients' charts; - Allows providers to keep track of the skills and knowledge that the transitioning youth needs to acquire before transfer of care; - May be used to ensure that all crucial education topics are covered; - May divide tasks based on chronological age; - Clinical decision support systems that remind clinical teams about steps for transition planning | - Spina Bifida Transition Program at the University of Wisconsin82; - Clinical Pathway Document developed by the ON TRAC program at British Columbia Children's Hospital145; - Checklist developed at the Center for Inflammatory Bowel Disease at Children's Hospital Boston146; - Rheumatology transition program at the Princess of Wales Children's Hospital, Birmingham, United Kingdom101; - Checklist available through the Endocrine Society's online practice management resource 79
Portable Medical Summary | - May include past medical and surgical history, list of current medications, allergies, immunizations, pertinent family and social history, most recent diagnostic and imaging studies, disease specific parameters (i.e., cardiac anatomy and physiology for patients with congenital heart disease), upcoming appointments, and contact information for health care providers; - Updated at each visit and a copy should be included in the medical record and given to the adolescent to keep; - May require special adaptation for those with intellectual disability to include non-written forms of communication such as pictures or tape recordings | - MyHealth Passport developed by the Good2Go Transition Program at the Hospital for Sick Children129,147; - Your Plan It developed by the ON TRAC program at the British Columbia Children's Hospital145
Meeting the Adult Provider | - May alleviate the lack of trust, fear, and anxiety that the youth and family may have related to acquiring a new adult provider; - May increase confidence and comfort among transitioning youth; - May promote higher rates of retention in adult clinics after transfer; - Joint clinics (or appointments) are a strategy for patients to meet the adult provider(s) before the transfer of care and help facilitate communication and convey trust among pediatric and adult members of the transition team; - Tours of receiving adult clinics are another strategy used to enable patients to meet the accepting adult health care team before transfer and acclimate the patient to their new health care setting | - Spina Bifida Transition Program at the University of Wisconsin82; - Cystic Fibrosis Transition Program at the University of Michigan148; - Young Persons Clinic at the Royal Manchester Children's Hospital149; - University Diabetes Center in Italy150; - Transition Pilot Program at St. Jude Children's Hospital148; - Sickle Cell Transition Program at Froedtert Hospital and Medical College of Wisconsin, Milwaukee151; - MAGICC approach in the Rheumatology Divisions at the Royal Hallamshire Hospital and Sheffield Children's Hospital105; - Royal Gwent Hospital diabetes program,120 Newport; - DON'T RETARD transition program for youth with juvenile idiopathic arthritis at University Hospitals Leuven, Belgium78; - The Liverpool Model, Liverpool Heart and Chest Hospital, United Kingdom121

##### Transition Completion

Written communication and good documentation may serve to promote continuity of care.36,48,66,68,83,97,104,130,152 Maintaining an up to date medical summary that is portable and accessible enables such communication.1,42,106,110,113,116 The medical summary for transition includes recommendations for treatments that work best physiologically and psychologically for the individual patient and family, as well as details such as advanced directives and provisions for affordable, continuous health insurance coverage.53,57,65,79,116,122 Providing the patient with a copy of the portable medical summary may help with communication and allows the patient an opportunity to include any personal information and advanced directives that he chooses.50,63,75,97,108 Personally controlled electronic health records or emerging smart phone applications can help support this effort.123 It may be helpful to have youth prepare their own referral letter to clarify their medical needs and set objectives for self-management, promoting identity development and responsibility.119

It is typically recommended that the referring pediatric team be available to the adult team as a resource immediately after the transfer of care to allow for a period of co-management with pediatric and adult providers.97,113 A transition coordinator, specifically, can help bridge communication between the pediatric and adult teams upon completing transfer of care.66,97 Some programs have included a celebration, including certificates, letters of gratitude to the health team, and graduation ceremonies.72,106,110,137,153 These strategies may address the feelings of abandonment and sadness with the loss of patient-provider relationship that youth have reported after transfer to adult health care.23

After complete transfer of care has taken place, the overall transition process should be evaluated to highlight areas for future improvement.54,97,103-105,112,117 Participation of youth and their families in evaluation of transition care also is recommended when developing and improving transition services.110 Continual transition service improvement will require the development more robust data collection methods and measurement tools that reflect the essential components of transition.134,154

Such tools could be developed in conjunction with electronic clinical decision support systems that aid health care providers in completing the sequential steps of transition planning, particularly since decision support and clinical information systems are two of the six “pillars” of the Care Model for Child Health.155 The systematic review conducted by Stinson and colleagues in September 2012 identified six transfer satisfaction measures, but found that none of these tools had well-established evidence of reliability and validity and most did not comment on how CSHCN or their families had been involved in the development and testing of these patient-reported outcome measures.142

### Transition in the Face of Patient Complexity (Guiding Question 1c)

Youth with special health care needs often have a complex array of medical and sometimes psychological or psychiatric conditions, reinforcing the need for individualized transition care. Each of the general components above can be personalized or augmented by the use of specific tools to address the complexity of health issues including comorbidities, the presence of both physical and intellectual disabilities, and confounding psychosocial circumstances.

The following may be helpful for addressing complexity in patient populations: maintaining a flexible policy regarding the timing of the transfer, adequate preparation through focused education and support, development of individualized transition plans, utilization of a transition coordinator, and facilitated communication between multidisciplinary providers and patient or family through use of a portable medical summary.

Our Key Informants noted that while all adolescents with a chronic condition would need some sort of transition support. Furthermore, their diversity in terms of conditions and complexity affects what is needed and where. For highly complex cases, the range and quantity of resources may be available, for example, only at centralized programs, often at academic centers. For some types of chronic conditions, on the other hand, and in the absence of multiple conditions, Key Informants recommended that community based programs can and should be developed.

## Guiding Question 2 Description of the Context for Implementing Transition Care

a. How widely available are programs or approaches to transition care within the health care setting for children/adolescents with special health care needs?
b. What are the resources needed to implement transition care?
c. What are the specific barriers to implementing transition care or processes for children/adolescents with special health care needs?
d. Who delivers transition interventions and what training is required to implement identified approaches to transition care for children/adolescents with special health care needs?

### Availability of Transition Programs (Guiding Question 2a)

The data on availability of transition programs are limited, but the little research that has been done suggests that these programs are not widely available. Although current numbers are unavailable, about one-half of diabetes centers in the United States reported having a structured transition program in 2010,^156^ and only 18 percent of pediatric rheumatology units in the United Kingdom had a dedicated adolescent clinic in 2000.^40^

Transition services might be especially inaccessible if one is receiving public services in childhood;65 a survey of state mental health administrators from across the United States found that only 5 percent reported the existence of any type of programs or services within the State mental health system to transition mental health treatment from the child to adult service system.157 Thus, the findings from limited research converge around some level of inaccessibility of transition programs and services, with anywhere from 5 to 50 percent of agencies or clinics offering such programs. Key Informants affirmed that availability and resources rather than standards defined as best practice and resources shape the landscape of transition care approaches seen in practice.

Dedicated transition programs are not only relatively inaccessible, but many pediatric clinics do not have formal plans for transitioning their pediatric patients with special health care needs to adult care. In a survey of providers of pediatric HIV care in the United States, 81 percent had designated a transition coordinator, but few clinics had established policies to define the details of transition.14 Established transition policies were also relatively uncommon in a survey of primary care pediatricians in the United States; only 13 percent had written policies about the transition from pediatric to adult care.158

Aside from information on the availability of specific transition programs or plans, the proportion of youth with special health care needs who are given information and assistance with transition (either within the context of a transition program or through their pediatric provider) is low. Nationally, only about 40 percent of youth with special health care needs meet criteria for adequate transition support, with the other 60 percent being unprepared for transition in at least one area.14,159 Similarly, among young adults with diabetes only 50 percent reported receiving specific adult provider or clinic recommendations. Fewer than 15 percent of participants reported receiving written transition materials, having a specific visit to discuss transition, or meeting the adult provider before transition.160 Finally, less than 40 percent of a sample of young adults with sickle cell disease received any preparation before transferring from pediatric to adult care.161

Perhaps in part because of a lack of transition support, just over 20 percent of youth with special health care needs nationally have successfully transitioned to adult care, defined by constructs such as having an adult provider who provides routine preventative care and having continuous health insurance coverage.162

In sum, the limited data on the availability of transition programs and information suggests that the majority of transitioning youth with special health care needs do not have access to a specific program to aid with their transition, nor to the necessary information or planning to make the transition a smooth process. Lack of access appears to be particularly pronounced for youth who are not receiving care within a medical home setting13 or are receiving public assistance, as well as youth with certain neurodevelopmental or psychiatric conditions,163 whose parents have less education, and who are racial/ethnic minorities.17,162

Our search for transition programs with information available online identified specific programs, presented in Appendix C. Few of these programs are evaluated in the published or gray literature. The gray literature search also retrieved a variety of online resources for transition care for individuals with special health needs.

### Resources To Implement Transition Care (Guiding Question 2b)

The resources needed to implement transition care vary, of course, by the type or complexity of the program or service. Commonly described resources include space, time, personnel, materials, and systems for knowledge transfer. Key Informants noted that successful implementation of a transition care program requires significant staffing and resources.

#### Space

Like all other health care programs, transition programs require dedicated space. Some transition programs use space to create a dedicated transition clinic.71,149,164-167 In other transition programs, space is needed to house a dedicated transition coordinator or other personnel within a pediatric clinic. Still other transition programs require space to convene transition-related activities such as peer support or mentoring groups.128,168

#### Time

Time is necessary to develop and implement transition policies, establish and maintain transition registries, prepare patients and families for transition, and transition planning and actual case transfer. For example, transition preparation, planning and case transfer all require communication and coordination between pediatric and adult providers.62,64,82,139,169-171 This requires patients and their families, pediatric providers, and adult providers to dedicate time to these activities.

It may be particularly important for adult providers to allow additional time for the first post-transition appointment because this may help build rapport with transitioning youth and their family and help the provider understand the youth's health care needs.82 Flexibility in terms of when the first adult appointment is scheduled may also be helpful. For example, scheduling the first adult provider appointment close in time to the last pediatric appointment, instead of following the regular visit schedule (which means that the patient might not meet with the adult provider for 6 months or more after transition), may ease the transition process and improve adherence.171

#### Personnel

Personnel are also required at each stage of the transition process from policy development to transition completion but are not used in the same way across transition programs. Some transition programs are separate, stand-alone clinics.56,164-166 These programs require front-end, clinical, and back-end staff to support transition-related activities. Other transition programs exist within pediatric clinics and require personnel with transition-specific responsibilities such as a transition coordinator.148,164,172-175 These programs must either hire staff whose responsibility is to manage transition processes or designate a portion of an existing staff member's responsibilities to transition-related tasks. Finally, other programs convene transition-related activities such as peer support or mentoring groups.128,168 These programs also must hire staff to coordinate and provide services.

Given the diversity and complexity of young adults with special health care needs, a multidisciplinary approach to transition seems most likely to ensure a transition process that meets the range of medical, cognitive, and social needs.51,57,61,87,111,138,144,151,176 Health care staff members involved in transition may include physicians, nurses, case managers, social workers, and peer mentors.87,144,151 Nonetheless, the Society of Adolescent Medicine emphasizes the need for one designated professional to take responsibility for the process together with the patient and the family.68 One of the more common suggestions is for that individual to be an assigned transition coordinator and advocate.39,42,43,50,71,74,76,78,82,99,101,103,107,109,116,134,152,177

A dedicated transition coordinator, either within the context of routine clinical care or in a specialized transition clinic, is a common approach to implementing a transition program.66,75,78,79,82,98,101,108,109,122,134,148,164,169,171-175,178 This is also a role that is valued by patients and their families who consider the availability of a transition coordinator to be more important than paper-based resources.134 The transition coordinator works with the transitioning youth to set developmentally appropriate goals, manage the transfer of information from the pediatric to adult provider, assist in making appointments with adult providers, arrange transportation, and facilitate the transfer from the family-centered orientation of pediatric care to the more individually oriented adult care system. The transition coordinator may attend the first adult appointment78,122,169,171 and sometimes follows-up with the patient multiple times after transition to ensure that they are satisfied and receiving the care they need.171 An advantage to assigning a care coordinator is that this staff member can assume a role that spans both pediatric and adult services as well as leverage already available community resources to meet individualized needs of transitioning youth.69,98,122

Several transition programs have reported using an advanced practice nurse as the transition coordinator,69,108,117,120,141,144,151,164 with the theoretical advantages being their capacity to attain dedicated time for transition initiatives and their ability to serve as an expert, educator, researcher, leader, and consultant.44,66,76,99,179 Alternatively, a community-based “navigator”, or facilitator, offers the advantage of being unencumbered by an affiliation with any particular service system.104,180

Regardless of whether transition coordinators are used, both pediatric and adult providers and their staff need training in issues of adolescence.36,89,151,181,182 Clinicians treating adolescents face specific challenges – particularly when the adolescent has special health care needs. These challenges may include determining the degree of autonomy versus family involvement appropriate to that individual, addressing risky behavior, and providing information in a way that is appropriate to their level of cognitive development (e.g., difficulties in considering long-term consequences of behaviors or nonadherence).

As is discussed in more detail in Guiding Question 2c, many providers (both adult and pediatric) do not receive specific training in providing care to adolescents and may be inadequately prepared to deal with adolescent issues such as puberty or lack of adherence to medication and treatment regimens because of the desire to be viewed the same as one's peers. For a transition program to be most effective, training in adolescent medicine can be helpful for the transition coordinator as well as for pediatric and adult primary care providers.

Further, pediatric providers may need training in transition processes and adult providers may need training in treatment of complex medical conditions beginning in childhood (e.g., cerebral palsy, Down syndrome, autism spectrum disorder); this is particularly true for adult physicians who treat patients with intellectual disabilities.36,139 In cases where training the adult providers is not feasible, or the specific condition that a patient presents with is too rare to warrant training, the availability of consultation with experts in specific childhood-onset conditions may increase adult providers' willingness to provide care to transitioning youth with special health care needs.124

Perhaps the most important resource needed to implement high-quality transition care is a productive collaboration between pediatric and adult providers.62,64,82,98,122,123,139,169-171 This collaboration can take different forms, such as scheduling one or a series of overlapping appointments with a pediatric and adult provider,64,79,95,122 a joint clinic that includes both pediatric and adult providers,61,98,109,170,180,183 or commencing appointments with an adult provider before transition.57,120,134,169 Other effective strategies are having the pediatric provider attend the first appointment with the adult provider170 and having the pediatric team followup with the transitioning youth after he or she has transitioned into adult care.169,180

Finally, trained personnel who are knowledgeable about the health insurance options available to transitioning youth with special health care needs are helpful to ensure that youth remain covered during the transition.184 Adolescents and young adults with a chronic disease are less likely to have health insurance than any other age group,169 and a trained staff person who can help them navigate changes in insurance coverage during the transition to adulthood can be valuable to avoid gaps in coverage or care. While the allowance for children to remain on parental insurance until age 26 and other expansions associated with the Affordable Care Act have the potential to mitigate some of these issues, it will still be important to provide support for navigating this changing benefits and access landscape.

#### Materials

Written guidelines36,62,89,102,144,169,185,186 can include information such as the age at which transition should be initiated, the age by which certain behaviors are expected to have occurred, how youth readiness will be determined, as well as the specific staff responsibilities for different aspects of the transition process.36,144

Although written guidelines can serve as a type of transfer checklist, formal transfer checklists designed to guide pediatric provider actions and transfer knowledge to adult providers are also available.50,62,79,82,171,187 A transfer checklist or plan might, for example, be kept on file with the pediatric provider and be sent to the adult provider. The plan may include information not necessarily contained in the medical record such as transition readiness, noncompliance issues, possible problems with insurance after transition, or other contextual factors.78,171

Information transfer ideally occurs well before the transition, so adult providers can understand the complications and challenges they might encounter.62 Information transfer well in advance may be particularly important if the patient's condition is severe and requires emergency care after transitioning from pediatric care but before the first adult ambulatory visit. Transition checklists can also be useful in helping families prepare their son or daughter with special health care needs to take on more responsibility for his/her health care.187

Several tools have been proposed to assess patient readiness and may be incorporated into guidelines and checklists. These need to be acquired or developed at the clinic level. Examples include the Readiness to Transition Questionnaire185 and a self-management scale to help providers determine how much of the youth's own care he or she has taken responsibility for (e.g., taking medications independently).62 Another tool is The Transition Readiness Assessment Questionnaire (TRAQ), which incorporates the Transtheoretical Model for the five stages of change into a 5-point ordinal scale for measurement of completed transition tasks specifically for youth with special health care needs.67 Disease specific transition readiness tools have also been developed for cystic fibrosis, cerebral palsy, and diabetes.64,98,188 The Self-Management Scale, piloted to assess transition readiness in youth with cystic fibrosis, was found to be a better predictor than age for success in transfer to adult care.62,64

Additionally, for youth with special health care needs who also have an intellectual disability, an assessment of cognitive, developmental, and adaptive functioning will be critical in determining transition readiness, the optimal level of involvement by parents, and to inform adult providers.51

In addition to written guidelines, transfer checklists, and readiness assessments patient-and family-centered educational resources encouraging autonomy, self-advocacy, self-care responsibility, and treatment adherence may also be important.50,78,87,89,144,187,189 Education materials that are available electronically, such as internet sites or mobile phone applications, are accessed more easily by young people.92,126,135 Teens have also identified games, animation, messaging, and chat features as desirable features for such education materials.135

Workbooks used as learning tools can help providers assess the patients' knowledge and understanding of their disease process and transition needs.83 Gilliam and colleagues144 describe the development of a workbook for transitioning youth with HIV/AIDS that uses a developmental approach to teach and reinforce life skills and health information.

Education strategies are an important part of improving adherence and preparing the youth to be responsible for his or her care. Providers may tailor the specific approach to patient education based on the resources of the clinic and the needs of the population.

#### Tools for Transferring Knowledge Between Providers

Key Informants recommended that care plans be in place at the time of patient transfer. Similarly, the literature asserts that a system to transfer knowledge and information from the pediatric provider to the adult provider is important.50,61,62,82,122,171,183,187,190,191 One example is the use of a transfer summary or checklist, kept on file with the pediatric provider and sent to the adult provider. The transfer summary or checklist includes important information not necessarily contained in the medical record such as a comprehensive summary of history of care, transition readiness, noncompliance issues, possible problems with insurance after transition, and recommendations for what might work best for the youth psychologically or physically.61,122,171

Towns and colleagues62 noted that the transfer of information would ideally happen well before the transition actually occurs, so that the adult care team can have a full understanding of the extent of complications and challenges they might encounter. Having this transfer occur ahead of the first adult appointment could also be important if the youth with special health care needs requires emergency care after transitioning from pediatric care, but before their first ambulatory visit with the adult provider. Key Informants uniformly endorsed this idea.

### Barriers to Implementation of Transition Care (Guiding Question 2c)

The literature describes several barriers to implementing transition care. We divided these barriers into systems and provider-related, and patient and family-related barriers.

#### Systems and Provider-Related Barriers

##### Cost and Insurance Problems

Changes in insurance and gaps in coverage are common in transition care, per the literature and the Key Informant interviews.17,51,57,58,66,81,87,97,108,111,122,123,140,144,159,169,182,192-195 Key Informants noted that the challenges to implementing seamless transition of care are complicated by significant differences between pediatric and adult health care practice, stemming from issues related to coverage, eligibility, and other financial disincentives.

When children and adolescents age out of Medicaid eligibility or their parents' insurance, options for obtaining coverage may be limited or nonexistent,108,140,193 and adolescents and young adults with special health care needs are less likely to have health insurance than any other age group.169 Up to one-third of youth experience gaps greater than 6 months in health care coverage when moving from a pediatric to adult provider,196 and between 15 and 30 percent of young adults with special health care needs have no insurance coverage.14,193

The age of transition often corresponds to a time when insurance coverage and benefits change. These insurance changes can result in decreased access to care for young adults and lack of coverage for those clinics that provide transition care further affecting reimbursement for services. Lack of insurance coverage during and after transition, as well as greater difficulties getting needed services for those receiving publically funded health care in adulthood 192 represents a significant barrier to implementing transition services, with serious implications for care throughout adulthood. Further, many young adults with special health care needs have difficulty maintaining employment, which can pose additional challenges to paying for health care. 122

Health care providers are often held to benchmarked standards for volume of patients seen and levels of reimbursement within their practice. Transition care requires a significant amount of provider time, which results in a decrease in the number of patients seen by an individual provider.78,111,189 However, this care does not result in a substantial increase in per visit reimbursement and can therefore translate into a financial loss to clinics that provide this type of service.187

In addition, transition care incorporates multidisciplinary services, which can be costly to those clinics that do not use these services for other patients. With the recent focus on pediatric medical homes, many pediatric clinics have greater access to multidisciplinary care,123 so this cost difference might be more significant for the adult clinics typically designed for individual focused care.

##### Differences in the Culture of Pediatric Versus Adult Providers

Differences in how pediatric and adult clinics are structured, as well as in expectations for transitioning youth, may pose another barrier to effective transition care.70,73,81,97,140,144,169,170,191,194,197 Given the initiation of the medical home concept in pediatric care, pediatric providers may be more accustomed to ensuring patients have followup appointments and prescription refills, whereas adult providers place more responsibility on the individual. Further, pediatric clinics may have greater familiarity with family-centered care, which is focused on developing a treatment plan that works for the youth with special health care needs and his or her family. Adult clinics, take a more patient-centered approach by treating the patient as an autonomous adult who makes his or her own informed decisions in collaboration with a provider70,73,194 Although this emphasis on personal agency and self-sufficiency for adult patients compared with pediatric patients is developmentally appropriate, it can be difficult and overwhelming for the transitioning youth.118,191 In particular, increasing emphasis on patient-centeredness in adult care, in which patients work in partnership with their clinicians to make health care decisions, may paradoxically cause undue stress on individuals with special health care needs especially as they transition.

The adult health care system currently tends to provide more fragmented care than the pediatric health care system, although an increasing emphasis on accountable care and models for implementing the adult medical home have significant potential to decrease fragmentation.170 Medical and psychosocial services are particularly separate, and medical and psychiatric records are sometimes kept entirely distinct even within the same medical system, even though transitioning youth with special health care needs often have comorbid psychiatric disorders that need to be addressed in addition to their complex medical needs.169 The need to make multiple appointments with different providers to get medical and psychosocial needs met through the adult care system, compared with the one-stop shop of pediatric providers, may pose a barrier to successful transition care. In particular, increasing emphasis on patient-centeredness in adult care, in which patients work in partnership with their clinicians to make health care decisions, may paradoxically cause undue stress on individuals with special health care needs especially as they transition.

##### Lack of Provider Training in Child-Onset Conditions

To some degree, adult providers lack in-depth training in childhood-onset conditions, having specialized in their training in adult medical care. Data from the literature support the Key Informant input that this is often the case; transitioning youth report that some adult providers do not have the skills or knowledge about childhood conditions to most effectively treat them.29,87,100,108,162,191,192,l,195,198,199

This lack of knowledge can lead to reluctance by adult providers to accept responsibility for adolescents who have complex physical and psychological needs70,113,124,144 leading to difficulty finding adult providers,36,58,64,80,102,170,187,191 especially for youth with significant cognitive limitations.51,170 As an example, in one study, more than half of pediatric neurologists were unable to find adult neurologists willing to care for patients with severe disabilities.170

#### Patient and Family-Related Barriers

##### Issues of Adolescent Development

Various developmental issues arise during adolescence that can be barriers to successful transition care.64,65,79,81,87,97,100,106,159,169,182,194,200 Risky behavior, substance abuse, and concerns about sexual health all peak at this time. Furthermore, adolescence is a time when peers take on greater importance, and youth with special health care needs can make great effort to appear “normal” to their peers. Many adolescents have limited experience with financial independence or making their own decisions and may have difficulty keeping appointments and being responsible for their own health care. They may not have developed the skills to negotiate independently the adult service system, which is more complicated and fragmented than the pediatric system.159 Many have not reached a level of maturity to be able to appreciate fully the long-term implications of their decisions.64,200,201

All of these behaviors, which are common to adolescence, can have a negative effect on the transitioning youth's ability to adhere to complicated medical regimens, and so are particularly troublesome for children with special health care needs.14 Further, because most providers are trained to provide care to children or adults, few providers have training in how to treat adolescents, and it can be very difficult to know the most effective way to deliver care to this population.134,144,151,159,194,202

Finally, some youth with special health care needs have conditions that worsen in adolescence, such as increased difficulties with glycemic control for youth with diabetes79,106 or the emergence of comorbid mental health problems, which are common among many youth with special health care needs.57,106,194

##### Problems With Adherence

Although likely confounded with issues of adolescent development (e.g., difficulty considering long-term implications of decisions and behaviors), differences in the structure of pediatric versus adult clinics (e.g., more hands-on followup to ensure adherence in pediatric clinics), or difficulties with insurance coverage, problems with adherence are common in transition-aged youth with special health care needs.57,65,75,81,87,97,109,144,169,182,194,198,200 Problems can include forgetting to take medications, running out of medications, and not showing up for scheduled appointments. Some youth with special health care needs may feel “burnt out” on managing their conditions and might not seek maintenance care.122

Non-adherence is one of the leading causes of organ rejection, and older adolescents and young adults have the highest rates of non-adherence.48,171,203 Young adult patients with diabetes have high rates of non-attendance after transfer to adult care and less frequent clinic contact is associated with poorer glucose control.56,63,130 Youth with diabetes have higher rates of hospitalization because of acute hyperglycemia within two years after transfer.23

##### Resistance to Changing Providers

Youth and parents may resist changing providers.51,66,70,75,81,82,87,97,100,118,122,169-171,182,191,195,197,199,204 It can be very difficult for families of youth with special health care needs to leave their familiar pediatric clinics for caregivers who are unfamiliar with their history,66,70,87 and to “start over” and develop relationship with new providers.51,73,108,204 Many youth express a preference for their pediatric providers and consider the adult service system to be impersonal.100,122 Further, youth and their families express concern that the quality of care will not be as good in the adult setting as that they are receiving in the pediatric setting.122,126,170,191,195,197 Reluctance about transitioning care to an adult provider can be compounded for youth who have medical conditions that carry with them stigma, such as HIV/AIDS.57,144,169,182

Resistance to changing health care providers can also occur on the part of the pediatric provider.66,70,204 Pediatricians may be reluctant to transfer care to another physician who does not have a longstanding relationship with the youth with special health care needs, either because pediatricians feel that they can provide the best care for the youth and family, or because they are unaware of community and adult resources.

#### Other Barriers

Other barriers to implementing transition care are mentioned sporadically in the extant literature. Not properly assessing and understanding the implications of cognitive delays among youth with special health care needs can pose barriers to implementing successful transition care.51,64,81,181 For these youth, providers must determine the extent to which parents should be involved in decisionmaking, and difficult behaviors (which are common among many youth with significant intellectual disability) may not be tolerated in adult provider offices.170,183

Similar issues arise for youth with physical disabilities, as parents may remain a critical part of decisionmaking if they provide substantial physical support.205 Experiencing multiple other transitions at the same time as the health care transition, such as graduating from school, finding employment, moving out of the parental home, and starting a postsecondary education program, can be overwhelming to youth and affect their willingness to participate in transition programming.73,195,198 Further, when youth with special health care needs attend a college program in another city, the physical distance between them and their primary care providers can be a barrier to successful transition care.192,195 Finally, the lack of well-defined criteria for determining transition readiness makes decisions about when transition should begin difficult, especially if transition is initiated too early or too late.73,109,194

### Delivery of Transition Interventions and Training (Guiding Question 2d)

#### Who Delivers Transition Interventions?

The National Heart, Lung and Blood Institute (NHLBI) recommends that transition teams include physicians, mid-level practitioners (e.g., nurses or physicians assistants), and social service workers from both pediatric and adult care settings.87 Transition programs that take this multidisciplinary approach may have multiple team members who can address the array of complex needs experienced by youth with special health care needs.

Although the specific personnel in each of these programs differ, a common thread throughout is to assemble the personnel to address both the medical and psychological needs of youth with special health care needs as they transition, including experts in disease specific conditions, adolescent development, psychosocial considerations, and case management.87,108

Several examples of comprehensive transition programs have been described, each one tailored to meet the specific needs of the focus population or condition. A clinic for youth with chronic rheumatic disease, for example, includes a nurse specialist, physiotherapist, occupational therapist, social worker, and the availability of vocational and sexual health counseling in addition to the primary care providers.64 A transition clinic for renal transplant patients includes a pediatric nephrologist, renal nurse, youth health specialist, renal pharmacist, renal dietician, and social worker.89 A transition clinic for youth with sickle cell disease includes direct-care nurses, a nurse educator, clinical nurse specialist, nurse manager, physicians, social workers, case managers, pharmacists, and emergency staff.151 Finally, one transition team for youth with HIV includes a case manager, social worker, health care provider, and youth advocate or peer partner.144

Depending on the specific needs of the youth, some of these professionals will play a more integral role in transition care, whereas others can be available for consultation as needed.180,206 In some programs, an individualized team is assembled after assessing the needs of the transitioning youth.141

More common are transition programs whose personnel include one pediatric provider, one adult provider, and a mid-level provider who facilitates the transition between the pediatric and adult provider.50,70,78,82,90,122,144,170 In these cases, the mid-level provider, often a nurse clinician, takes the role of the “transition specialist” by coordinating care from the pediatric to the adult provider and ensuring that the appropriate information is transferred. In one model, the nurse practitioner manages the care of the transitioning youth during his or her last years with the pediatric provider and then becomes the primary provider once the youth has transitioned to the adult care system.144

Although it is theoretically possible that the multidisciplinary team-based approach advocated by the NHLBI may result in better transition outcomes than programs that include health care providers only, these types of programs have not been tested against each other, and thus evidence for superiority is lacking. Resource barriers to implementation of team-based care in independent practices may be substantial, so practicality of this type of approach should also be studied.

#### What Additional Training is Necessary?

Ideally both pediatric and adult providers should receive training in issues of adolescence,36,89,98,134,181,182,189 and at the least, the mid-level provider serving as the transition specialist should receive this training.98,151 Further, for adult providers and for the transition specialist, additional training in complex conditions that begin in childhood (e.g., cerebral palsy, Down syndrome, autism spectrum disorder, congenital heart disease) is helpful;29,141 this is particularly true for adult physicians who treat patients with intellectual disability.36,139 Osterkamp and colleagues181 describe an example of modules for training adult providers and include topics such as family-centered care, development of the healthy versus the chronically ill adolescent, and the Health Insurance Portability and Accountability Act. Training in adolescent medicine (to pediatric or adult providers) may address issues such as substance use, emotional wellbeing, and sexual health.134 Callahan and colleagues70 suggested that physicians trained in a medicine-pediatrics residency program might be particularly well suited to receive this type of training and to provide adult care to young adults with special health care needs.

Finally, because the transition specialist will need to work effectively with multiple providers and systems of care, training in how to promote collaboration among providers and team members may be helpful.178

## Guiding Question 3 Description of the Existing Evidence (Evidence Map)

a. What patient groups/clinical conditions are represented in studies on the use and evaluation of transition care for children/adolescents with special health care needs?
b. What is the length of followup in studies on the use and evaluation of transition care for children/adolescents with special health care needs?
c. What outcomes are measured in studies on the use and evaluation of transition care for children/adolescents with special health care needs?

### Patients and Conditions Represented in Evaluation Studies (Guiding Question 3a)

We identified 25^25,56,89,128,148-150,164-166,172-175,180,207-215, 239^ studies reported in 30 publications25,56,89,101,109,128,148-150,154,164-166,168,172-175,180,207-216, 239 that evaluated a system of purposeful transition care from the peer reviewed literature. We sought studies that measured effectiveness of a transition program and did not limit to any types of programs. This means we included studies of any approach to a system of transition care even if the evaluation outcome was defined as successful transfer, or if the system focused primarily on the transfer process. As discussed earlier in this technical brief, we use the term “transfer” generally to describe the point-in-time when a case is transferred from pediatric to adult care; we use the term “transition” to communicate a more comprehensive set of support processes and care that ideally begin before and extend some period of time after the moment of transfer. See Figure 1 for detailed reasons for exclusion.

Figure 1 Literature flow diagram

Notes:

* Records could be excluded for multiple reasons.

† 25 studies reported in 30 publications

The literature flow diagram illustrates the number of records retrieved from searches of electronic databases (n=2238) and from other searches (i.e., hand search) (n=45). A total of 2283 records were retrieved for screening. At the level of abstract screening, 1588 records were excluded. 695 records were promoted for full text review. The diagram lists reasons for exclusion for 386 citations: population not youth (n=15); population did not have a special health need (n=7); publication did not address transition from pediatric to adult care (n=110); not a heath care setting (n=30); did not address a Guiding Question (n=231); unavailable (n=18); and duplicate (n=3). The diagram notes that the exclusion reason counts do not tally as publications could be excluded for multiple reasons. The figure indicates that 309 papers were retained for Guiding Questions 1, 2, 3, and/or 4. Of these, 30 papers (25 studies) were retained for Guiding Question 3.

Among the 25 studies, eight56,150,164-166,173,210,213, 239 studied transition care for adolescents with diabetes. Five studies25,89,172,174,207 studied transition care in adolescents who had undergone organ transplant; all but one of these focused on kidney transplant. Two studied transition care in sickle cell disease.180,212 The remainder studied a variety of conditions including congenital adrenal hyperplasia,149 HIV,208 epilepsy,209 juvenile idiopathic arthritis,175 spina bifida,214 cystic fibrosis,148 inflammatory bowel disease,215 or included a patient population comprising more than one chronic disease.128, 211, 239

Twelve studies were conducted in Europe: eight in the United Kingdom,56,149,164,166,207,211,212,217 one in Germany,25 one in Spain,213 and two in Italy.150,173 Eight studies were conducted in the United States;128,148,165,174,180,212,214, 239 three studies were conducted in Canada;89,168,209 and one study was conducted in Australia.172 One study included data from the United Kingdom and Australia.208 Interpretation of information from evaluation studies of transition care published in English from countries other than the United States must consider differences in the structure and financing of health care systems across countries.

Very few studies used a concurrent comparison group. Some studies compared survey responses of individuals who had participated in transition care with those of individuals who had not, with transition generally not occurring concurrently. This is because most interventions are implemented at the system level and provided to all relevant patients at the same time; thus, these studies generally relied on data from individuals who transitioned before the services were available as comparators.

Outcomes were generally patient-reported and focused mostly on issues such as satisfaction with the process or health-related quality of life. Some clinical outcomes are available in the literature; these include objective measures such as glycosylated hemoglobin (HbA1c) levels for patients with diabetes and rates of organ rejection among transplant patients. Generally, however, studies defined successful transition as attendance in adult care (transfer) or continued adherence to medication. Thus, although the programs offered comprehensive support rightly regarded as transition care, evaluations often focused on outcomes traditionally regarded as an index of the more limited concept of transfer.

In addition to the evaluation information on transition care for youth with special health needs that we found in the indexed literature, we catalogued relevant transition care resources, programs, and projects found in the gray literature. We include a detailed list of projects and resources in Appendix C and a summary of ongoing studies and funded projects in Appendix E.

### Length of Followup (Guiding Question 3b) and Outcomes Measured (Guiding Question 3c) in Evaluation Studies

#### Diabetes

The most commonly studied group of transitioning youth was individuals with diabetes (Table 3). Numbers of young people with type I and type II diabetes have been steadily increasing,218 and some evidence suggests that hormonal shifts in adolescence may complicate the maintenance of metabolic control.219,220 Coupled with the need to participate in an adult health care system, maintaining good control in the transition to adulthood can be challenging in this population.

Table 3 Overview of diabetes transition studies

Citation Location Study Description Length of Followup | Population | Tnrasition Care Model | Setting(s)/Provider(s) | Outcome(s) Reported | Results
Cadario F, et al., 2009^173^ Italy Retrospective cohort (for identifying cases and collecting clinical data) with cross sectional survey data 1 year | Youth with type I diabetes in structured transfer plan (n=30) or unstructured method (n=32) | Structured transfer plan, including a designated pediatrician transition coordinator working with an endocrinologist to transfer care | Hospital Adult physicians, transition coordinator and endocrinologist | Date of first admission, mean HbA1c, clinic attendance rates, transition experience | Patients in the structured program had shorter transition, better clinic attendance and lower HbA1c. All reported favorable experience
Gholap N, et al., 2006^166^ U.K. Retrospective comparison with data from another published study NR | Adolescents and young adults ages 16 to 25 with type I diabetes (n=68) | Young person's diabetes clinic that met monthly. Based on the Alphabet strategy, a mnemonic based approach to care: Advice; Blood Pressure lowering; Cholesterol and creatinine control; Diabetes control; Eye examination; Foot examination; use of Guardian drugs | Outpatient diabetes clinic (young person's diabetes clinic) Diabetologist, pediatrician, 2 “associate specialists”, a pediatric and adult nurse specialist, a dietician and Asian link worker | Clinic attendance, HbA1c, hypertension, nephropathy, retinopathy, presence of complications | Patients who attended young person clinic had lower non-attendance (12% vs. 24.6%), lower mean HbA1c (8.4% vs. 9.5%), better blood pressure monitoring (100% vs. 88%), higher rates of screening for nephropathy, and lower rates of nephropathy (5% vs. 21%) compared with data from a recently published multicenter study.
Holmes-Walker DJ, et al., 2007^164^ Australia Quality improvement assessment included retrospective collection of clinical data 12 months before participation and prospective data collection after clinic attendance. No comparison group. NR | Young adults with type I diabetes aged 15-25 years (n=191) | Transition coordinator or diabetes educator scheduled appointments for young people and provided reminders via phone, email or text; afterhours phone service was available | Young adult diabetes clinic within an adult referral hospital Diabetes educator Transition coordinator | Frequency of clinic visits, HbA1c, diabetic ketoacidosis, admissions | HbA1c improved significantly after a median of 5 visits (p<0.001); 82% attended clinics in the last 6 months; diabetic ketoacidosis admissions fell by 30%
Kipps S, et al., 2002^56^ U.K. Retrospective cohort study of four regions, each of which employed a different transition approach Up to 2 years after transfer | Individuals with type I diabetes aged older than 18 years (n=229) | Four different transfer procedures at the district level: transfer from pediatric clinic to adult clinic, transfer to a young adult clinic, transfer with introduction to the adult provider before transfer, initial move to an adolescent clinic before moving to an adult clinic | 4 health districts in the U.K. Young adult clinic | Age at transfer, clinic attendance rates, HbA1c | Clinic attendance dropped from 94% two years pre-transfer to 57% two years post transfer. Clinic attendance ranged from 29% to 71% across districts with higher rates among patients who met the adult provider before transfer
Lane JT, et al., 2007^165^ Nebraska, U.S. Retrospective cohort study comparing outcomes in patients participating in the specialized clinic to patients who directly entered adult endocrine clinics 3 years | Young adults with type I diabetes aged 15 to 25 years seen in young adult clinic (n=96) or in general endocrine clinic (n=153) | Specialized clinic including an endocrinologist, 2 nurse educators and 2 dieticians. Services included substantial focus on education as well as group classes. The general endocrine clinic (comparison group) met in the same place and included a multidisciplinary provider team but without a class and with longer intervals between visits. | University diabetes center Specialized young adult diabetes clinic | Glycemic control measured via HbA1c | HbA1c levels did not change in either clinic overall. Within the highest tertile of HbA1c, patients in the young adult clinic had the largest decrease
Van Walleghem N, et al., 2006,^210^ 2008,^168^ and 2012^154^ Manitoba, Canada Comparison of two cohorts – a younger group who had used the system, and an older group that had transferred before its implementation. Up to one year after referral to the program | Youth with type I diabetes aged under 18 years who participated in model (n=84) and older group aged 19-25 years who had transitioned without support (n=64) | Systems navigator model, administrative coordinator maintains phone and email contact with patients to identify barriers. Delivery methods include a comprehensive website, a bimonthly newsletter, a drop-in group, and educational events. | Community clinics, diabetes education resource center | Number of medical and diabetes educator visits, first year loss to follow up, diabetes-related hospitalizations, chronic complications, barriers to care in adult system | 40% who did not have access to the navigator dropped out of medical care versus 11% who did
Vanelli M, et al., 2004^150^ Cross sectional survey of patient experience, with pre-transition and post-transition HbA1c data collected from medical records. No comparison group. One year post transition and at study initiation | Adolescents with type I diabetes (n=73) with a mean age at transition of 21.0±0.95 years | Protocol for an uninterrupted procedure for transfer including introduction to the adult provider before transition and attendance by the pediatrician at the first adult visit. Transition occurred when the patient and parents agreed | Pediatric, adult specialty clinic Pediatric and adult providers | Patient satisfaction, attendance, HbA1c | 94% of patients reported being satisfied with the process. Consensus about readiness to transition was achieved within 2 to 4 visits for 66% of patients. Mean HbA1c one-year post transition was 7.6±1,1% compared with 8.8±2.1% pre-transition
Vidal M, et al., 2004^213^ Pre-post, no comparison group 1 year | Young adults with type I diabetes and a mean age of 19±1.3 years at transition (n=80) | Therapeutic Education Program for young adults transferring to adult care, including coordinated transfer visits, initial extended evaluation by adult staff (90 minutes), a pact to commit to the insulin therapy protocol with goal-setting, 4 group sessions with relatives, 3 to 6 individual visits over 6 months | Hospital-based adult outpatient clinic Adult endocrinologist and nurse; 12 to 15 hours dedicated to each patient, half of which were in group sessions | Meal plan composition, total daily insulin, HbA1c, body weight, number of hypoglycemic episodes | No changes in meal plan composition, no differences in daily insulin dose, increase in proportion of patients performing readjustments of insulin dose, decrease in HbA1c and in the number of hypoglycemic episodes

Abbreviations: HbA1c = Glycosylated hemoglobin; U.K. = United Kingdom; U.S. = United States

Transition care interventions studied to date have included use of a transition coordinator (n=2),164,173 attendance of the pediatrician at the adult care visit(s) (n=2),150,173 education and skill building (n=3),165,166,213 a specialized young adult clinic (n=4),56,164-166 and use of technology for education and reminders (n=2).164,210 In five models, patients transferred directly into an adult clinic.56,150,173,210,213 Practical assistance with scheduling was used in two programs.164,213

The most common diabetes-related outcomes were HbA1c levels (a marker for glycemic control),56 diabetes-related hospitalizations,164,210 and adult service attendance.56,150,173,210 Seven studies used HbA1c levels as outcomes.56,150,164-166,173,213 Patient satisfaction was the focus of two studies.150,173

None of the studies was entirely prospective. Five included some sort of comparison group,56,165,166,173,210 with three using concurrent comparators,56,165,173 although the analyses were retrospective. Three studies did not use a comparison group at all.150,164,213 In general, studies were published as quality improvement evaluations, rather than with the intention of providing research inferences.

No two studies evaluated precisely the same transition care intervention, although some intervention components were common across studies. Nonetheless, there is clearly a need for replicated studies and for the use of concurrent comparison groups to identify best practices. All studies reported either improved health outcomes or maintenance of health.

#### Solid Organ Transplant

A small body of literature25,89,172,174,207 is available on the transition of pediatric patients with organ transplants to adult care (Table 4). Four of the five studies25,89,172,207 focus on kidney transplant patients, with the remaining study174 on liver transplant. All of the studies on kidney transplant patients include the evaluation of a specific transition oriented clinic – either one for youth alone or a joint pediatric-adult clinic. The one study on liver transplant patients evaluated the role of a transition coordinator.174 This was the only prospective study, but the study did not use a concurrent control group, relying on historical comparators who had transitioned before implementation of the coordinator role.174 The four studies on kidney transplant patients25,89,172,207 report clinical outcomes, including organ rejection and mortality. The study on liver transplant patients174 reports on patient satisfaction, psychological benefits, and medication adherence, confirmed via blood draw.

Table 4 Overview of transplant transition studies

Citation Location Study Description Length of Followup | Population | Transition Care Model | Setting(s)/Provider(s) | Outcome(s) Reported | Results
Annunziato RA, et al., 2013^174^ U.S. Prospective evaluation using historical (asynchronous) comparators who transferred before establishment of a transition coordinator 1 year | Patients in the pediatric liver transplant program (n=20) and historical cohort (n=14) | Transition coordinator who assisted with preparation, served as a liaison between pediatric and adult services, provided care coordination, provided outreach before and after transfer, and implemented research protocols to evaluate transition programming | Academic medical center; transition coordinator was a licensed clinical psychologist | Medication adherence measured via patient report and blood levels; Psychosocial outcomes including developmental skills and acceptability of the transfer process | Medication adherence was significantly better for patients who had access to the transition coordinator compared with the cohort who did not
Chaturvedi S, et al., 2009^172^ Australia Retrospective review of case notes followed by a patient survey 12 months | Pediatric kidney transplant recipients (n=11) | Transition clinic, development of self-management skills and a written transition summary | Children's hospital renal clinic Transition coordinator, transition adult nephrologist, and transition nurse | Serum creatinine levels, episodes of acute rejection, number of inpatient days, frequency of scheduled appointments and missed appointments | Patient health outcomes were fairly stable during the 12 months before and 12 months following transfer as measured by number of acute rejection episodes and hospital inpatient days. Adherence, as measured by attendance of scheduled appointments dropped from 73% before transfer to 57% after transfer
Harden PN, et al., 2012,^207^ and 2013^109^ U.K. Comparison of two cohorts – a younger group who had used the system, and an older group that had transferred before its implementation Between 1 and 60 months after transfer | Young adult kidney transplant recipients (n=21); before 2006 (n=9); between 2006 and 2010 (n=12) | Integrated pediatric-young adult joint transition clinic and care pathway plus a young adult clinic located in a college sports center that included a youth worker. Patients are seen jointly by pediatric and adult teams from ages 15 – 18 and then transfer to the adult clinic at age 18. Patients are seen by providers without family members present to promote autonomy, and then meet with family members to review progress and management plans | Adult renal center and two pediatric renal centers (joint transition clinic) | Rates of acute organ rejection, morbidity, admissions | Six of nine patients who transitioned before implementation of the transition clinic had transplant failure compared with no transplant failures in the group that transferred after implementation of the transition clinic
Pape L, et al., 2013^25^ Germany Retrospective cohort One year prior and one year after transfer | Pediatric kidney transplant patients (n=66) in a transition clinic (n=15), patients transferred directly to an adult nephrologist (n=25), patients attending an adult nephrology clinic with a phase of alternate appointments over 1 to 2 years before transfer | Specialized transition clinic led by a specialized adult neurologist | Academic medical center (specialized transition clinic) | Survival, stability of immunosuppressive therapy, use of steroids and patient satisfaction | There was no difference in changes in clinical outcomes before and after transfer between the settings. Patient satisfaction was higher among those who transitioned via a specialized adolescent clinic compared with the patients who transferred to an adult nephrologist, either directly or by alternating appointments
Prestidge et al., 2012^89^ Canada System-level pre-post using historical controls 2 years | Kidney transplant recipients pre- transition clinic (n=34); transferred after opening transition clinic (n=12) | Multidisciplinary transition clinic where patients are seen every 4 to 6 months until transition in addition to attending standard transplant clinic. Transition team members see each patient. Specific educational goals include identifying the primary care provider, demonstrating medication knowledge, recognizing signs of rejection and infection, appraisal of ability to self-manage and awareness of reproductive health issues | Children's hospital, which is the referral center for renal transplantation in the region. Specialized transition clinic. Team includes a dedicated pediatric nephrologist, renal nurse, youth health specialist, renal pharmacist, renal dietician and social worker. | Deaths, allograft losses, graft function, costs per patient | The time to either graft loss or death was better for individuals transferred to adult care after implementation of the transition clinic than for individuals who transferred to adult care before implementation of the transition clinic. The average annual cost was less per patient for those who participated in the transition care clinic

Abbreviations: U.K. = United Kingdom; U.S. = United States

#### Other Conditions

We identified an additional 12 studies128,148,149,175,180,208,209,211,212,214,215,239 on a range of conditions (Table 5). Two studies focused on sickle cell disease,180,212 and three studies included patients with a variety of conditions,128,211,239 while the remainder of the studies had one clinical focus.148,149,175,208,209,214,215

Table 5 Overview of other special health needs transition studies

Citation Location Study Description Length of Followup | Population | Transition Care Model | Setting(s)/Provider(s) | Outcome(s) Reported | Results
Andemariam B, et al., 2013^180^ Connecticut, U.S. Retrospective chart review After 5 years of implementation E+ only Outcome is transfer | Patients with sickle cell disease ages 16 to 24 years who began transition process between 2007-2012 (n=47) | Transition program combined between existing pediatric center with newly-formed adult center. Components included patient education, transitional phase included family meetings | Pediatric hospital and academic medical center | Demographics, clinical information (genotype, 3 year admission history for vaso-occlusive crisis or acute chest syndrome episodes, hydroxyurea or chronic transfusion therapy program), and transition clinic attendance. | 68% patients had successfully transitioned. Risk factors for unsuccessful transition included: greater distance to travel and older age at time of initiation of transition. Patients with less severe disease (genotypes and no chronic transfusion therapy) were higher risk for unsuccessful transfer.
Bent N, et al., 2002^211^ U.K. Cross sectional NA | Youth with longterm physical disability (n=245) | Young Adult Teams, including multidisciplinary teams including a consultant in rehabilitation medicine, a psychologist, therapists and a social worker | 4 health care regions in the U.K., 2 with young adult team services and 2 with ad hoc services | Participation in society based on the international classification of functioning, disability and health | Individuals in the Young Adult Teams were more likely to participate in society than individuals who used ad hoc services
Betz CL, et al., 2010^214^ California, U.S. RCT 4 months followup | Youth with spina bifida, ages 14-18 years (n=65) | Transition Preparation Training, cognitive-behavioral program (8 sessions in a 2-day workshop) to facilitate development of transition plan | Academic children's hospital Training program administered by trainer | Well-being, role mastery, and self-care practice | No groups differences between groups
Bundock H, et al., 2011^208^ U.K. and Australia Comparison of satisfaction with transition care among youth with HIV compared with youth with diabetes NR | Adolescents with perinatally acquired HIV in (n=21); Adolescents attending diabetes transition service (n=39) | Outpatient services using sequential approach to transition for HIV patients Outpatient clinic using direct transition model for patients with diabetes | Academic health science center clinic Pediatric infectious disease specialist, adult senior lecturer in HIV genitourinary medicine, adult HIV clinical nurse, adult psychologist | Patient satisfaction | Patients in both groups reported that transition from pediatric to adult care went smoothly and that transition was associated with improved health care
Chaudhry SR, et al., 2013^148^ Michigan, U.S. Retrospective survey NA | Adults with cystic fibrosis (n=91) in a transition program vs. non-program participants | Structured transition program beginning early in adolescence, focusing on developing independence. Included a transition coordinator and participation of the adult pulmonologist in the pediatric clinic until readiness is achieved | Academic medical center | Patient satisfaction, perceived health status | Patient who went through a transition program were more satisfied with care before transferring to adult care
Gleeson H, et al., 2013^149^ U.K. Retrospective record review NA | Individuals with congenital adrenal hyperplasia aged 16 years and older who attended pediatric clinic from 1992 to 2009 (n=61); pediatric clinics (n=37); Young Person Clinic (n=24) | Young Person Clinic at which the youth is introduced to an adult endocrinologist | Children's hospital Young Person Clinic had both pediatric and adult endocrine teams in attendance | Adult clinic attendance | Introduction of the Young Person Clinic had no effect on rates of engagement, with 50% lost to followup after transfer to adult services
Greveson K, et al., 2011^215^ London, U.K. Pre-post survey | Adolescents with inflammatory bowel disease (n=25) | Joint bimonthly transition clinic based on the Royal College of Nursing Model and including six key aspects: self-advocacy, sexual health, education and vocation, independent health care behavior, psychosocial support, and health and lifestyle. Adolescents enter at age 16 and remain in the transition service until the health care provider and parents agree that transfer to adult care is appropriate. | Pediatric specialty center | Time spent in transition clinic, patient knowledge of disease and factors important to transition | 5 of the 21 pre-transfer respondents transferred to the adult service. Mean time spent in transition clinic was 8 months.
Hankins JS, et al., 2012^212^ Tennessee, U.S. Pre-post pilot study 18 months preceding start of transition program and 18 months after start of the transition program | Youth with sickle cell disease aged 17 to 19 years (n=83) | Transition Pilot Program including a tour of adult SCD programs, lunch discussion with pediatric staff and scheduling of the first adult visit by the pediatric hematology case manager | Pediatric hospital Pediatric hematology staff | Proportion of pediatric patients fulfilling their first adult hematology appointment | Most (74%) of the transition program participants completed their first adult hematology appointment within 3 months as compared with 33% of those who did not participate in the transition program
Huang et al., 2014^239^ California, U.S. Randomized Controlled Trial After the 8-month intervention | Youth ages 12-20 years with diabetes, inflammatory bowel disease, and cystic fibrosis (n=81) | Disease management intervention based on social cognitive theory and delivered via Web site and text messaging | Patient education (technology-based disease management) Pediatrician, public health educator | Disease self-management, health-related self-efficacy, patient-initiated communications, receipt of curriculum materials, | Relative to controls, transition program patients had improved disease management task performance, health-related self-efficacy, and patient-initiated communication
Jurasek L, et al., 2010^209^ Canada Cross sectional NA | Adolescents with epilepsy (n=97) | Nurse-led Adolescent Epilepsy Transition Clinic | Children's hospital | Patient satisfaction, understanding, and fears at 2 to 3 months after first visit | Patients and caregivers were satisfied with the transition process
Maslow G, et al., 2012^128^ Rhode Island, U.S. Pre-post Length of time from pre- to post-test varied from 3 to 10 months One or more years following program participation (mean age of 20.6 years) | Individuals with a chronic illness (14 different conditions) aged 13 to 19 years (mean age 15.4 years) (n=20) | The Adolescent Leadership Council 10-month group mentoring program based on the Positive Youth Development framework | Children's hospital Pediatric and psychiatry residents, child life therapists, medical students, supervised by pediatric and psychiatry attending physicians; Had a fulltime director and clinical care was provided pro bono | Loneliness, chronic disease management, self-advocacy and successful transfer to adult care | Participants reported less loneliness and improved self-advocacy after participation in the mentoring program. There was a small increase in transition readiness scores for program participants
McDonough JE, et al., 2006a,175 2006b,101 and Shaw KL, et al., 2006^216^ U.K. Systems-level pre-post; Cross sectional 6 month followup 12 months after clinic visit | Adolescents with juvenile idiopathic arthritis aged 11 to 18 years (n=308) | Program of transitional care coordinated within each center with a program coordinator funded for one day per week. Patients worked through a series of templates that were developmentally appropriate and focused on home, health, and school. Informational resources were provided to patients and their families. | 10 pediatric rheumatology centers | Satisfaction with care, health-related quality of life, and arthritis-related knowledge | Overall satisfaction scores improved significantly for adolescents and their parents after transition program implementation. Higher scores of acceptability for the local program coordinator compared with paper-based resources.

Abbreviations: NA = not applicable; NR = not reported; U.K. = United Kingdom

Two transition care interventions used a transition coordinator.148,175 Five transition care interventions used multidisciplinary teams to provide care jointly,148,180,208,211,215 and one evaluated a separate young adult clinic.149 One transition care intervention provided direct scheduling of visits,212 one was a mentoring group that met over 10 months,128 and another used a generic 2 month intensive internet- and text message-based intervention followed by a 6 month review period.239 Patient education was a common component of transition care.128,148,175,180,209,214,215,239

## Guiding Question 4 Issues and Future Research

a. What are the implications (e.g., ethical, privacy, economic) of the current level of diffusion and of further diffusion of transition care for children/adolescents with special health care needs?
b. What are possible areas of future research for transition care for children/adolescents with special health care needs and which research designs are most appropriate to address these research topics?

### Implications (Guiding Question 4a)

Documented decreases in adherence to medications and clinic appointments following transition are reasons to maximize successful transition.23,203,221 Decreases in adherence are associated with worsening clinical outcomes including increased hospitalizations secondary to poorly controlled diabetes23 and increased allograft loss in kidney transplant recipients203 following transition, suggesting that the risks of unsuccessful transition are significant and that a paucity of transition programs could have substantial implications.

Poor reimbursement for transition services affects the ability of clinics to provide this care, which is often time intensive and multidisciplinary.18,108,222 Up to 70 percent of physicians have reported that compensation adversely affected their ability to provide appropriate care for children with special health care needs because of lack of time, lack of patient insurance coverage and low reimbursement for the extra time required.222 One review identified billing codes that can be used by clinicians to obtain appropriate reimbursement for these services, but it is unclear whether many or most physicians and coders are aware of how to use these codes appropriately.223

Given poor reimbursement and an overall dearth of transition programs, the reach and success of interventions may be affected by the income of the patient's family or type of insurance14,18 as access to health care in the adult system is often limited for those patients with Medicaid insurance coverage.170 Historically, the adolescent and young adult years marked a time during which a child was no longer covered under a parent's insurance.224 This impact may be minimized in future years by the implementation of the Affordable Care Act in which individuals can remain on their parents' insurance plans up to age 26. Inequality exists in overall access to health care in the adult clinical setting with those of lower income or without private insurance receiving less access to health care, which affects medical care post-transition.225

Racial disparity may also occur, with some research suggesting that transition from pediatric to adult care is less successful in non-Hispanic black and Hispanic patients compared with Caucasian patients14 and less successful in minority patients in general compared with Caucasians even in the setting of the pediatric medical home.17,18 In addition, a higher familial education level has been associated with more successful transition, which may imply a lack of health literacy in the lower educated families whose educational needs are not met in the current transition systems.18 Timing of transition may also affect medical outcomes after transition to adult care with one study of diabetic young adults suggesting that transfer to an adult clinic at a younger age was associated with worse outcomes.133

One barrier to successful transition is the lack of experience and training of adult clinicians in chronic diseases that were historically pediatric diseases.45,54,68,191,226,227 In addition to the lack of experience of the clinicians, many adult clinics are not designed to treat adults with behavioral or developmental concerns, causing some to raise ethical concerns about whether it is appropriate to transition those patients to an adult provider unprepared to care for them.170

There are particular risks for patients with developmental or cognitive delay in that the current transition process most often involves an adult clinic, which has more of an individual focus rather than family focus when the patient's needs may require family-focused care.45,170,228 Integrated systems of support for multidisciplinary care that are available in many pediatric practices less often present in the adult clinic setting although the concept of the adult medical home is growing in concert with emphasis on population health and accountable care.54,211,225,229

Finally, developing transition programs will need to address the question of privacy as more providers and types of providers have access to the patient's medical information..68,229,230

In sum, the implications of the current diffusion of transition care are that many young people who need support in moving from pediatric to adult care are not receiving that support, and the adult system of care is unprepared to receive them. The risk of these patients falling through the cracks is substantial as they have serious and ongoing medical needs.

### Areas for Future Research (Guiding Question 4b)

Methodologic and substantive issues should be addressed in future research about transition care. Methods issues include a common and validated definition of transition success, a need for more rigorous study designs, dedicated funding, and inclusion of a broader range of clinical research perspectives (i.e., involvement of pediatric and adult researchers). Areas and opportunities for future research include: technology, information about health care systems, disease progression, patient-specific transition, educational research, and cost research.

#### Definition of Successful Transition

A major barrier to transition research is a lack of well-defined outcome measures.106,231-233 Possible metrics to evaluate success could include perceptions of success and satisfaction with the transition process (on the part of clinicians, adolescents, and parents), improved or stable disease-specific medical outcomes,169,229 decreased or stable cost of health care, or educational milestones in a patient's ability to care for themselves or navigate the health care setting.144,233,234 Without clear clinical or functional outcomes identified, most studies have focused on qualitative measures including clinicians' or patients' perceptions of success without objective measurements to support the claims of success of individual transition processes. No validated measures of transition have been developed.231

Future methodologic research should focus on identifying or developing objective measures of successful transition as well as transition tools.114,161 Quality of life and personalized outcomes identified by the adolescents participating in transition care could be significant outcome measures, but others should be developed as well.225,231-233,235 In addition, very few studies provided data on long-term followup, which could be important for considering the ultimate success of transitioning.

#### Study Design

Randomization in transition research can be problematic as medical care is multidisciplinary, and isolating any one intervention or holding constant concomitant interventions, even in a randomized controlled trial is difficult.170,174,211,234 However, rigorous evaluation of these multidisciplinary transition programs is still needed.

Transition is a process often beginning in early adolescence and continuing through young adulthood. Ideally, researchers will design studies to evaluate participants before, during, and after the transition period. These studies would therefore need to be long, and thus may be cost prohibitive.131,171,232,234 One method to obtain prospective data for evaluation of transition would be the development of disease-specific or location-specific core transition data sets that could be used for research of the transition process over the short term period as well as longitudinally.234

An alternative to using longitudinal studies to evaluate the impact of transition on patient outcomes and assess overall improvement in the transition process is quality improvement initiatives and evaluation designs.20,59,236,237 Quality improvement research could help identify best practices for transition,59 factors within transition that affect outcomes positively or negatively,144,169,232 as well as individual predictors for successful transition.169,232

#### Funding

Funding streams generally focus on specific diseases, but the field of transition research would benefit from more generalized research that can identify effective methods across disease groups. Identifying funding streams that are nondisease specific may be challenging but important.234

#### Involvement of Pediatric and Adult Researchers

Traditionally, transition efforts and transition research has been led by pediatric providers even though adult providers are an essential component to the transition process. Future research should include both pediatric and adult researchers.234 Research will also require involvement of primary care providers in addition to subspecialty care providers when applicable. No research has identified an optimal timing of transfer when multiple provider specialties are involved in an individual patient's care. Therefore, no data are available to guide which service should transfer first during the transition process.

#### Technology

The use of technology in transition has particular promise for adolescents, who tend to be comfortable users of technology. Novel uses of technology to improve adherence to medications, to provide education regarding their medical disease, to identify medical deterioration earlier, and to communicate with their health care providers should be further considered in future studies.106,234,238-9Given some of the disparities in access to care as children with special health care needs transition to adulthood may benefit from expansion and evaluation of uses of technology in the form of telemedicine.

One study reported improvement in medication adherence and decreased rejection in pediatric liver transplant patients who received text message reminders.234 Another study also suggested that a disease generic intervention including text messaging components was associated with improvements in disease management task performance, health-related self-efficacy, and patient-provider communication,239 but more research is needed in the area to confirm and expand on these concepts. In addition, the use of social media and its role in improving transition care would be an important area of research.

#### Information about Health Care Systems

A paucity of data exists regarding how individual systems affect transition. Transition programs would vary based on the health care system in which the care is provided. Some pediatric and adult clinic systems would share a core electronic medical record whereas other systems function more independently requiring development of standardized methods to communicate the complex medical history of the transitioning patients.

While research focusing on generalizable transition care processes is essential, the development of validated tools to aid a variety of systems in implementing successful transition is also necessary. Evaluations of transition care programs will need to specify the type of systems in which the transition was performed and what resources or tools were required to implement the program.

Documentation of resources could include specific programs such as city based transportation programs available to patients or clinic and institutional resources such as personnel, educational opportunities, and electronic medical record support. Identifying the differences and similarities within successful transition processes could be beneficial to the medical community as individual clinical systems modify components of the transition processes to work within their unique systems.

#### Natural Progression of Diseases

With improved clinical outcomes, many chronic diseases that were formerly seen only in pediatrics are now affecting adults. The adult course of these diseases is largely unknown, and therefore, aspects of transition specific for these diseases remain unclear. For these diseases, prospective tracking of the natural course and complications of these diseases will be necessary to determine what components of transition will be required when caring for adults with these diseases.170,225,229

#### Patient-Specific Information

Appropriate timing and necessary tools for successful transition may vary by severity or type of disease. Transition for individuals with a mildly debilitating disease could focus on disease self-management skills and medical system navigation whereas a transition program for individuals with severe disease may focus on palliative care and end of life challenges. The desired outcomes of the transition process could vary based on severity of disease as well.

Research of these programs would need to control for these differences in care and outcomes. In addition, the hypothesis that children with different diseases may require different transition processes requires further investigation since no study has evaluated the efficacy of disease specific versus general transition processes in a comparative manner.

Intellectual disability can be associated with some chronic diseases that affect children transitioning to adult care. The severity of disability influences the degree with which a young adult can manage their own care and therefore affects measures of successful transition. In addition, physical developmental delays or impairment can affect the ability of individuals to navigate the medical system independently. Successful research in transition would need to include stratification for cognitive ability and developmental delay for the subjects if variability exists. Future research efforts should evaluate the success of transition program modifications for patients with cognitive or physical impairments.

Behavioral health care is important in the transition process to provide support and services to address coping with chronic medical diseases and treatment, nonadherence, and psychological effects of their chronic disease. Few studies have addressed this aspect of transition care. Studies evaluating the role of behavioral health within the transition process will be critical.

#### Educational Research

As transition programs progress, one area of research that will be important is educational research to determine whether adult providers, multidisciplinary team members, adolescent providers, and developmental medicine providers are trained in the tenets of successful transition for adolescents with special health care needs.44,93,131

Educational research can also focus on the education provided to patients and parents throughout the transition process.44,93,131,159

#### Cost Research

We identified one cost study. The study took place in England so the relevance of the results to the United States health care system may be limited. The study did identify increased costs associated with the transition period, but did not find that an organized transition program was more resource intensive than ad hoc services.211 Researchers should attempt to report the costs associated with transition implementation and service. This information can then be compared with the costs of unsuccessful transition in this patient population.174,235