# Background

There is no uniformly accepted age at which pediatric care is inappropriate and adult care should be sought for every patient. Nonetheless, some practices do have age cut-offs, and there comes a time when adult providers may be better able to serve the needs of patients whose medical concerns are more adult in nature, including for example reproductive and other issues. In addition, the inclusion of adults in pediatric practices can create discomfort and challenges for other pediatric patients and their families, and pediatricians can find themselves addressing medical issues of adults for which they are less prepared. Therefore, at some point, most pediatric patients should and do move into the adult care system.

An effective transition process from a pediatric to an adult health system should ensure continuity of developmental and age-appropriate care. In 2002 the American Academy of Pediatrics (AAP), the American Academy of Family Physicians (AAFP), and the American College of Physicians (ACP) coauthored a consensus statement: “The goal of transition in health care for young adults with special health care needs is to maximize lifelong functioning and potential through the provision of high-quality, developmentally appropriate health care services that continue uninterrupted as the individual moves from adolescence to adulthood.”1

This process can be challenging, particularly for children and youth with special health care needs (CSHCN), defined as individuals having or being at risk of “a chronic physical, developmental, behavioral, or emotional condition and who also require health and related services of a type or amount beyond that required by children generally.”2 Examples of adolescent populations with special health care needs that need transition support range widely, including those with chronic illnesses such as diabetes or sickle cell disease and individuals with developmental disabilities that are associated with a host of challenges ranging from higher risks of specific health outcomes to the need for special support in navigating the health care system.

The National Alliance to Advance Adolescent Health estimates that chronic health conditions affect approximately 25 percent of the 18 million U.S. young adults ages 18 to 21 who should be transitioning to adult-centered health care. Each year, approximately 750,000 young people in the United States with special health care needs transition to adult care.3,4 Although they only represent an estimated 15.1 percent (2009/2010 National Survey of Children with Special Health Care Needs) to 19.8 percent (2011/2012 National Survey of Children's Health) of children aged 0 to 17 years, CSHCN account for as much as 70 percent of child health care expenditures,5-7 and most of these individuals will survive into adulthood as the life expectancy of children with chronic illness continues to increase.8,9 Over the past few decades, the prevalence of childhood chronic conditions also has been steadily increasing, with an associated increased risk of a range of health problems and persistent impact into adulthood for many affected individuals.10,11

Fewer than half of CSHCN aged 12 to 17 years report that they receive adequate support and services for their transition to adult care.12-15 The proportion is even lower for ethnic minorities and children living in poverty,16,17 with gaps in appropriate transitions to adult care ranging from approximately 15 to 25 percent.17,18 The low rates of transition support reported by families may reflect the fact that only one-third of pediatricians report making referrals to adult physicians and less than 15 percent report providing transition education materials to adolescents and their parents.19

Potentially serious health-related consequences may be associated with suboptimal or incomplete transition to adult care. Gaps in care in transitions have been associated with poor health outcomes, increased hospitalizations and more complications and failure to access care in populations with diabetes, arthritis, and sickle cell disease.20-24

Examples of programs to enhance transition for CSHCN include use of a separate transition clinic, engagement of a transition coordinator, and a phased transfer within a clinical system.20,25-27 The potential for these programs to be effective is offset by barriers that include a lack of time and resources to address transition issues, inadequate reimbursement, hesitancy of families and providers to dissolve long-standing therapeutic relationships, and gaps in residency training for both transition processes and medical management of adults with childhood-onset chronic diseases.24,28-30 Additionally, CSHCN face broader challenges, including issues related to insurance, entitlements, guardianship, and eligibility for adult community-based services.2,31

Nonetheless, several guidelines, panels, and other groups coalesce around the need for good transition care for this population in particular. Healthy People 2010^32^ includes a goal that all young people with special health care needs receive the services needed to make necessary transitions to all aspects of adult life, including health care. The AAP states that “optimal health care is achieved when every person at every age receives health care that is medically and developmentally appropriate.”1

One of the six core objectives of the U.S. Department of Health and Human Services, Health Resources and Services Administration, Maternal and Child Health Bureau (MCHB) is that “all youth with special health care needs will receive the services necessary to make appropriate transitions to adult health care, work, and independence.”33 Despite this consistency in intent, there is little evidence to date about what constitutes an effective transition program for this population of patients,34 although a literature of program descriptions, evaluations and research on the topic is growing.

The Affordable Care Act has several provisions reflecting federal emphasis on facilitating health care transitions for youth. Relevant provisions include extension of insurance for dependents and foster children up to age 26, protections that eliminate preexisting condition exclusions and lifetime coverage limits, Medicaid expansion, and creation of a new Center for Medicare and Medicaid Innovation that will include development and evaluation of patient-centered medical home models for individuals with complex needs.35

In 2011, the AAP, AAFP, and ACP36 reaffirmed the 2002 jointly published consensus statement1 and made further recommendations using a decision algorithm. The 2011 report describes practice-based recommendations and core elements, or components, of health care transition: transition policy, transitioning youth registry, transition preparation, transition planning, transition and transfer of care, and transition completion.36 The components underscore the key concept that transition care is a process that involves actionable steps by both pediatric and adult provider. Transition is not a single event or passive process and the recommendations differentiate between health care transition and provider transfer, noting that, “[h]ealth care transfer is an element of transition and has a defined end point that may vary from patient to patient.”36

Six common elements of transition planning that occur in both pediatric and adult practice are policy, patient registry, preparation, planning, transfer, and completion;37 these are summarized in Got Transition,38 a federally funded initiative. This initiative is a widely known resource to aid in transition planning and process, and when asked about standard components of transition planning, the Key Informants on this project consistently pointed to this approach. Importantly, the initiative describes standard elements for inclusion, but allows for the elements to be designed and implemented in a targeted manner to match the specific needs of the clinical condition or health care system. Thus, while the standard underlying elements are consistent, they are deployed in a targeted and specific manner. We elected to use these elements as a framework for organizing this literature.

A transition policy serves to educate staff about best practices for health care transition, with privacy and consent procedures shared with providers, staff, patients, and families. A patient registry is recommended for transition planning and monitoring outcomes. The Transition Readiness Assessment helps prepare patients for transition and identify gaps in knowledge or skills that may present educational opportunities for improvement in self-management. The Health Care Transition (HCT) Action Plans, including Portable Medical Summary and Emergency Care Plan are recommended for the planning phase. The Transfer of Care Checklist is also a useful tool for clinicians during the transfer of care phase. Finally, the pediatric care provider and team should follow up with the adult care team three months after transfer of care to ensure successful completion.37

Notable initiatives that make use of these six components include the National Health Care Transition Center multi-site learning collaborative, which piloted the six core elements of transition, and the Center for Medical Home Transition which includes visits from nurse case manager and sharing of information.20 The National Health Care Transition Center also developed an assessment tool for use in the empirical evaluation of transition programs.20,37

Nonetheless, the currently available body of literature is primarily descriptive with only few studies that measure the effectiveness of any particular transition interventions, including use of the Got Transition framework. Much of the research emphasizes the transfer component of transition, and completion of transfer is a common outcome. Although we attempted to review the state of the literate on the complete transition process, the availability of literature across elements was clearly not consistent and that is reflected in our results.

## Technical Brief Objectives

Despite a lack of rigorous research on the topic, various organizations have suggested that transition planning is particularly important for children and adolescents with special health care needs. Descriptive studies have been published and the empirical literature is growing, but the study data needed to conduct a meaningful systematic review of transition effectiveness either is not yet available or has not been published. We therefore developed a Technical Brief to report existing programs or approaches for transition care and describe the current state of the research.

A Technical Brief is a rapid report of an emerging intervention for which there are limited published data and too few completed research studies to support definitive conclusions. The goals of the Technical Brief are to provide an objective description of the state of the science, identify a potential framework for assessing the applications and implications of the intervention, summarize ongoing research, and present research gaps. A technical brief is not intended to be a comprehensive systematic review but should provide the reader with an overview of available research, practice and to some degree, perspective, around a given clinical intervention.

For this Technical Brief, we proposed Guiding Questions to summarize the purpose and components of transition care for CSHCNs, describe the clinical practice areas that evaluated strategies for transition care, outline possible training and barriers to transition care, and identify directions for future research. We outlined the report scope and priorities with input from Key Informants identified as individuals who were engaged in the practice, implementation, or evaluation of existing programs and systems of transition care for youth with special health needs.

This report focuses specifically on transitions of care from pediatric to adult services for individuals with a chronic health condition. It does not include transitions within the adult health care system or the transition of youth without a special health care need. Similarly, we confined the scope of the proposed Guiding Questions to transition in health care, with the understanding that the provision of clinical services is a part of a comprehensive evaluation of successful transition that would likely include educational, psychosocial, and occupational supports.

## Guiding Questions

We presented the following questions to the Key Informants:

### Guiding Question 1 Description of Interventions for Transition Care

a. What are the goals of transition care and what are the theoretical advantages and disadvantages?
b. What are the common components of transition care interventions or processes used in clinical practice for children/adolescents with special health care needs?
c. How do currently used approaches to transitioning health care address the complexity of health issues including comorbidities and the presence of both physical and intellectual/developmental disabilities?

### Guiding Question 2 Description of the Context for Implementing Transition Care

a. How widely available are programs or approaches to transition care within the health care setting for children/adolescents with special health care needs?
b. What are the resources needed to implement transition care?
c. What are the specific barriers to implementing transition care or processes for children/adolescents with special health care needs?
d. Who delivers transition interventions and what training is required to implement identified approaches to transition care for children/adolescents with special health care needs?

### Guiding Question 3 Description of the Existing Evidence

a. What patient groups/clinical conditions are represented in studies on the use and evaluation of transition care for children/adolescents with special health care needs?
b. What is the length of followup in studies on the use and evaluation of transition care for children/adolescents with special health care needs?
c. What outcomes are measured in studies on the use and evaluation of transition care for children/adolescents with special health care needs?

### Guiding Question 4 Issues and Future Research

a. What are the implications (e.g., ethical, privacy, economic) of the current level of diffusion and of further diffusion of transition care for children/adolescents with special health care needs?
b. What are possible areas of future research for transition care for children/adolescents with special health care needs and which research designs are most appropriate to address these research topics?