# Ongoing Studies

Study Name Location Trial Identifier | Sponsors and Collaborators Study Status | Population Disease/Condition Age | Interventions / Groups | Primary Outcome Measures
Transition of Adolescents and Young Adults with Diabetes from Pediatric to Adult Care University of Kansas Medical Center Research Institute NCT01109797 | Kurt Midyett, MD, CDE Completed, results not published Start: April 2010 Complete: May 2012 | - Type I Diabetes or type 2 diabetes managed with insulin; - Age 16-29 | Behavioral: Transition Social Behavioral Intervention Behavioral: Diabetes Transition Clinic | - change in self-efficacy; - change in diabetes knowledge diabetes quality of life; - family conflict; - treatment satisfaction
Diabetes Care Management Compared to Standard Diabetes Care in Adolescents and Young Adults with Type 1 Diabetes (TransClin) University of Western Ontario, Canada NCT01351857 | University of Western Ontario, Canada Juvenile Diabetes Research Foundation Recruiting Start: April 2012 Complete: December 2016 | - T1D diagnosis; - Age 17-20 | Other: Transition Coordinator | - change in one outpatient adult endocrinology visit
Primary Care Transition Study Children's Hospital of Philadelphia NCT01750892 | Children's Hospital of Philadelphia Enrolling by invitation Start: October 2012 Complete: December 2013 | - 1 chronic condition and/or cognitive disability; - Age 19 or older | Behavioral: REACH for Independence Behavioral: Transition Consult Other: Study Materials | - Successful transition to an adult provider
Adolescent, Caregiver, and Young Adult Perspectives of the Transition from Pediatric to Adult Care for Sickle Cell Disease: A Preliminary Evaluation of the Sickle Cell Disease Transition Program St. Jude Children's Research Hospital NCT01569971 | St. Jude Children's Research Hospital Plough Foundation Health Resources and Services Administration Recruiting Start: March 2012 Complete: September 2013 | - Adolescents with SCD; - Young Adults with SCD; - Age 12-30 | Other: Assessment (focus groups and questionnaires) | - Grounded theory qualitative analysis of data
The LETS Study: A Longitudinal Evaluation of Transition Services Holland Bloorview Kids Rehabilitation Hospital, Toronto, Ontario, Canada NCT00975338 | Holland Bloorview Kids Rehabilitation Hospital Neurotrauma Foundation Active, not recruiting Start: September 2009 Complete: September 2013 | - Diagnosis of cerebral palsy or acquired brain injury; - Diagnosis of spina bifida; - Age 16-23 | Other: Prospective LIFEspan Other: Prospective Non-LIFEspan Other: Retrospective Non-LIFEspan | - Maintenance of continuous care
Congenital Heart Adolescents: Program of Transition Evaluation Research (CHAPTER) University of Alberta NCT01286480 | Not reported Active, not recruiting Start: January 2011 Complete: December 2012 | - Moderate or complex congenital heart disease or acquired heart disease; - Age 15-17 | Behavioral: Clinic-based Educational Intervention | - change in patient satisfaction questionnaire (PSQ-18); - change in parent/guardian Patient Satisfaction Questionnaire (PSQ-18); - change in patient knowledge of his/her CHD (MyHeart score)
The CHAPTER II Study-Congenital Heart Adolescents Participating in Transition Evaluation Research University of Alberta NCT01723332 | University of Alberta Heart and Stroke Foundation of Canada Recruiting Start: November 2012 Complete: May 2015 | - Moderate or complex CHD; - Age 16-17 | Behavioral: Educational Behavioral: Self-management | - Excess time to first ACHD clinic appointment
Transition Study of Inflammatory Bowel Disease (IBD) Patients from Pediatric Gastroenterologist to Adult Gastroenterologist Vanderbilt University NCT00360022 | Vanderbilt University Unknown Start: August 2006 Complete: December 2012 | - Confirmed diagnosis of IBD; - Age 16 and older | Other: Transition program | - Decrease IBD flare at 1 year
Implementation of a Pediatric-to-Adult Asthma Transition Program University of Calgary NCT01521247 | University of Calgary Recruiting Start: April 2010 Complete: December 2013 | - Clinical diagnosis of asthma; - Age 17-19 | Other: Asthma Transition Program | - Asthma Quality of Life Questionnaire with Standardized Activities
Internet-based Educational Program to Promote Self-Management for Teens with Hemophilia The Hospital for Sick Children NCT01477437 | The Hospital for Sick Children, Toronto, Canada Completed Start: November 2011 Complete: March 2013 | - Diagnosis of mild, moderate or severe hemophilia A or B; - Age 13-18 | Other: Teens Taking Charge: Managing Hemophilia Online-Online self-management intervention | - Disease-specific knowledge gained
Long-term Survival with HIV: Psychological and Behavioral Factors Associated with the Transition from Adolescence to Young Adulthood National Cancer Institute NCT00026806 | National Cancer Institute Completed Start: July 2001 Complete: June 2005 | - HIV-infected adolescents; - Age 13-24 | NA | - NA
Health literacy-disparities and transition in teens with special healthcare needs Research Institute Nationwide Children's Hospital Medicaid managed plan in Southwest Ohio 5R01MD007160-03 | National Institutes of Health National Institute on Minority Health and Health Disparities Ongoing Start: September 2011 End: July 2016 | - Special healthcare need; - Age 15-17 | NA | - NA
Outcomes after transfer of pediatric renal transplant patients to adult providers University of Virginia 5F31NR011237-02 | National Institute of Nursing Research Completed Start: August 2009 End: May 2011 | - Kidney transplant recipients; - Ages 16-25 | NA | - NA
From adolescence to adulthood: persons with and without diabetes Carnegie-Mellon University 5R01DK060586-12 | National Institutes of Health National Institute of Diabetes and Digestive and Kidney Diseases Ongoing Start: July 2013 End: June 2017 | - Diabetes; - Ages 22-24 | NA | - NA
Transitioning from childhood to adulthood: the impact of perinatal HIV infection New York State Psychiatric Institute 5R01MH069133-10 | National Institute of Mental Health Ongoing Start: December 2012 End: November 2013 | - Perinatally HIV infected youth; - Perinatally HIV exposed, uninfected youth | NA | - NA
Barriers & facilitators to health care: transitioning youth with special needs Okumura, Megie University of California, San Francisco AHRQ 5K08HS017716-05 HSRP20084171 | Agency for Healthcare Research and Quality Ongoing Start: September 2012 End: September 2013 | - Youth and young adults complex chronic conditions | NA | - NA
Cystic fibrosis as a model of health care transition for chronically ill youth Children's Hospital Corporation 5K23HL105541-03 | National Heart, Lung, and Blood Institute Ongoing Start: July 2012 End: June 2016 | - Adolescents and young adults with cystic fibrosis | NA | - NA
Patient-provider interventions to improve transition to adult care in SCD Cincinnati Children's Hospital Medical Center 5K07HL108720-03 | National Heart, Lung, and Blood Institute Ongoing Start: August 2013 End: July 2015 | - Sickle Cell Disease; - Ages 16-24 | NA | - NA
A health care transition randomized trial for minority youth with special health care needs Tuchman, Lisa HRSA and MCHB HSRP20123116 | Maternal and Child Health Bureau Ongoing through 2015 | - Not specified | Not specified | - Not specified
Service transitions among youth with autism spectrum disorders Shattuck, Paul NIMH HSRP20102263 | National Institutes of Health; National Institute of Mental Health Ongoing through 2014 | - Autism spectrum disorder | Not specified | - Not specified
Youth with complex needs: transition to adulthood plans Rehm, Roberta S NICHD HSRP20102257 | National Institute of Child Health and Human Development Completed 2012 | - Complex chronic conditions | Not specified | - Not specified
Developmental Disabilities Health Care E-Toolkit McMillan, Elise Special Hope Foundation | Special Hope Foundation Ongoing | - Developmental disability | NA | - NA
Family-centered transition project Hagner, David HSRP20111046 University of New Hampshire, Institute on Disability | Maternal and Child Health Bureau Completed 2011 | - Autism spectrum disorders; - Age 16-18 | Family-Centered transition planning model compared to usual care | - Not specified