# Reasons for Exclusion

Exclusion Code | Exclusion Reason | Count
X-1 | Not youth | 15
X-2 | Population does not have a special health need | 7
X-3 | Publication did not address transition from pediatric to adult health care | 110
X-4 | Not a health care setting | 30
X-5 | Original research and does not address a guiding question | 102
X-6 | Not original research and does not address a guiding question | 130
X-7 | Unavailable | 18
X-8 | Duplicate | 4

## References

1 Program coordinates care, resources for medically complex children. Hosp Case Manag. Oct. 2003;11(10):145-8. X-3, X-6. [pmid: 13677693].
2 Transition from paediatric to adult endocrine care in patients with childhood onset growth hormone deficiency. J Pediatr Endocrinol Metab. Feb. Suppl 2. 2004;17:267-71. X-6. [pmid: 15116950].
3 Health assessments not holistic in transition. Learning Disability Practice. 2004;7(2):6. X-6.
4 Few adolescents with special health care needs receive adequate transition from pediatric to adult-oriented health care. AHRQ Research Activities. 2005;(300):9. X-6.
5 Hospitalization patterns change as young people with congenital heart disease transition from adolescence to adulthood. AHRQ Research Activities. 2007;(323):4. X-3.
6 GAO report explores adult transition challenges for youth with SMI: bipartisan lawmakers introduce legislation to address barriers, provide grants. Mental Health Weekly. 2008;18(26):1-3. X-6.
7 From the American Academy of Pediatrics: Policy statements--Supplemental Security Income (SSI) for children and youth with disabilities. Pediatrics. Dec. 2009;124(6):1702-8. X-3, X-4. [pmid: 19948637].
8 Project seeks replicable service model for youth in transition. Mental Health Weekly. 2009;19(34):3-4. X-6.
9 Clinical Report--Supporting the Health Care Transition From Adolescence to Adulthood in the Medical Home. Pediatrics. 2011;128(1):182-200. X-8. [pmid: 21708806].
10 Abstracts. Adoption & Fostering. 2013;37(4):426-9. X-1, X-2, X-3.
11 Agwu AL, Fairlie L. Antiretroviral treatment, management challenges and outcomes in perinatally HIV-infected adolescents. J Int AIDS Soc. 2013;16:18579. X-6. [pmid: 23782477].
12 Allen D. Into the abyss. Learning Disability Practice. 2008;11(5):9. X-6.
13 Allen D, Gregory J. The transition from children's to adult diabetes services: understanding the ‘problem’. Diabet Med. Feb. 2009;26(2):162-6. X-6. [pmid: 19236619].
14 Allison S, Baune BT, Roeger L, et al. Youth consultation-liaison psychiatry: how can we improve outcomes for young people with chronic illness?. Aust N Z J Psychiatry. Jul. 2013;47(7):613-6. X-6. [pmid: 23430841].
15 Al-Yateem N. Child to adult: transitional care for young adults with cystic fibrosis. Br J Nurs. Jul. 26. Aug. 8. 2012;21(14):850-4. X-2. [pmid: 23252167].
16 Amaria K, Stinson J, Cullen-Dean G, et al. Tools for addressing systems issues in transition. Healthc Q. Oct. 2011;14(Spec No 3):72-6. X-6. [pmid: 22008577].
17 Andemariam B, Owarish-Gross J, Grady J, et al. Identification of risk factors for an unsuccessful transition from pediatric to adult sickle cell disease care. Pediatr Blood Cancer. Apr. 2014;61(4):697-701. X-8. [pmid: 24347402].
18 Annunziato RA, Shemesh E. Tackling the spectrum of transition: what can be done in pediatric settings?. Pediatr Transplant. Nov. 2010;14(7):820-2. X-6. [pmid: 20946515].
19 Arango P. Family-centered care. Acad Pediatr. Mar-Apr. 2011;11(2):97-9. X-3. [pmid: 21282085].
20 Arcelus J, Cashmore R. Child to adult: managing the transition. British Journal of Healthcare Management. 2008:9-14. X-6.
21 Archbold S. Children with cochlear implants--what is needed--and what is wanted in the long-term?. Cochlear Implants Int. Jun. Suppl 1. 2010;11:225-7. X-3. [pmid: 21756618].
22 Baines JM. Promoting better care: transition from child to adult services. Nurs Stand. Jan. 14-20. 2009;23(19):35-40. X-6. [pmid: 19326623].
23 Barendse RM, aan de Kerk DJ, Kindermann A, et al. Transition of adolescents with inflammatory bowel disease from pediatric to adult care: A survey of Dutch adult gastroenterologists' perspectives. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):609-16. X-7.
24 Bates K, Bartoshesky L, Friedland A. As the child with chronic disease grows up: transitioning adolescents with special health care needs to adult-centered health care. Del Med J. Jun. 2003;75(6):217-20. X-6. [pmid: 12929331].
25 Beacham BL, Deatrick JA. Health care autonomy in children with chronic conditions: implications for self-care and family management. Nurs Clin North Am. Jun. 2013;48(2):305-17. X-3, X-6. [pmid: 23659815].
26 Beattie RM. Symposium 6: Young people, artificial nutrition and transitional care: Nutrition, growth and puberty in children and adolescents with Crohn's disease. Proc Nutr Soc. Feb. 2010;69(1):174-7. X-6. [pmid: 19968909].
27 Begley T. Transition to adult care for young people with long-term conditions. Br J Nurs. May. 9-22. 8. 2013;22(9):506-11. X-5. [pmid: 23752622].
28 Bell LE, Bartosh SM, Davis CL, et al. Adolescent Transition to Adult Care in Solid Organ Transplantation: a consensus conference report. Am J Transplant. Nov. 2008;8(11):2230-42. X-6. [pmid: 18822088].
29 Benden C. Specific aspects of children and adolescents undergoing lung transplantation. Curr Opin Organ Transplant. Oct. 2012;17(5):509-14. X-3. [pmid: 22941318].
30 Berge JM, Patterson JM, Goetz D, et al. Gender differences in young adults' perceptions of living with cystic fibrosis during the transition to adulthood: a qualitative investigation. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2007;25(2):190-203. X-5.
31 Betz CL. Health care transitions of youth with special health care needs: the never ending journey. Commun Nurs Res. Spring. 2008;41:13-29. X-6. [pmid: 18822668].
32 Betz CL, Linroth R, Butler C, et al. Spina bifida: what we learned from consumers. Pediatr Clin North Am. Aug. 2010;57(4):935-44. X-5. [pmid: 20883883].
33 Betz CL, Smith K. Measuring health care transition planning outcomes: Challenges and issues. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):463-72. X-7.
34 Bhat AH, Sahn DJ. Congenital heart disease never goes away, even when it has been ‘treated’: the adult with congenital heart disease. Curr Opin Pediatr. Oct. 2004;16(5):500-7. X-6. [pmid: 15367842].
35 Bhatia S, Ahmad F, Miller I, et al. Surgical treatment of refractory status epilepticus in children: clinical article. J Neurosurg Pediatr. Oct. 2013;12(4):360-6. X-3. [pmid: 23971636].
36 Bickman L, Lambert EW, Andrade AR, et al. The Fort Bragg continuum of care for children and adolescents: mental health outcomes over 5 years. J Consult Clin Psychol. Aug. 2000;68(4):710-6. X-3. [pmid: 10965645].
37 Bindels-de Heus KG, van Staa A, van Vliet I, et al. Transferring young people with profound intellectual and multiple disabilities from pediatric to adult medical care: parents' experiences and recommendations. Intellect Dev Disabil. Jun. 2013;51(3):176-89. X-1. [pmid: 23834214].
38 Blackman JA, Conaway MR. Adolescents With Cerebral Palsy: Transitioning to Adult Health Care Services. Clin Pediatr (Phila). 2013. Nov. 25. X-5. [pmid: 24275216].
39 Blomquist KB. Healthy and ready to work--Kentucky: incorporating transition into a state program for children with special health care needs. Pediatr Nurs. Nov-Dec. 2006;32(6):515-28. X-6. [pmid: 17256289].
40 Blomquist KB. Health, education, work, and independence of young adults with disabilities. Orthop Nurs. May-Jun. 2006;25(3):168-87. X-5. [pmid: 16735848].
41 Blum RW. Introduction. Improving transition for adolescents with special health care needs from pediatric to adult-centered health care. Pediatrics. Dec. 2002;110(6 Pt 2):1301-3. X-6. [pmid: 12456948].
42 Brennan LJ, Rolfe PM. Transition from pediatric to adult health services: the perioperative care perspective. Paediatr Anaesth. Jun. 2011;21(6):630-5. X-6. [pmid: 21414078].
43 Broadhurst S, Yates K, Mullen B. An evaluation of the My Way transition programme. Tizard Learning Disability Review. 2012;17(3):124-34. X-4.
44 Brodie L, Crisp J, McCormack B, et al. Journeying from nirvana with mega-mums and broken hearts: The complex dynamics of transition from paediatric to adult settings. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):517-26. X-7.
45 Brooks F, Bunn F, Morgan J. Transition for adolescents with long-term conditions: event to process. Br J Community Nurs. Jul. 2009;14(7):301-4. X-6. [pmid: 19597382].
46 Bruder MB. The role of the physician in early intervention for children with developmental disabilities. Conn Med. Sep. 2004;68(8):507-14. X-3. [pmid: 15468622].
47 Bucuvalas JC, Alonso E, Magee JC, et al. Improving long-term outcomes after liver transplantation in children. Am J Transplant. Dec. 2008;8(12):2506-13. X-3. [pmid: 18853949].
48 Burke R, Liptak GS. Providing a primary care medical home for children and youth with spina bifida. Pediatrics. Dec. 2011;128(6):e1645-57. X-3. [pmid: 22123894].
49 Burke SD. Diabetes in transition: Factors affecting diabetes self-management in college students. University of Illinois at Chicago. Health Sciences Center. 2004. X-5.
50 Burns JJ, Sadof M, Kamat D. The adolescent with a chronic illness. Pediatr Ann. Mar. 2006;35(3):206-10. 14. 6. X-6. [pmid: 16570487].
51 Busse FP, Hiermann P, Galler A, et al. Evaluation of patients' opinion and metabolic control after transfer of young adults with type 1 diabetes from a pediatric diabetes clinic to adult care. Horm Res. 2007;67(3):132-8. X-5. [pmid: 17065819].
52 Camacho CB, Hemmeter J. Linking youth transition support services: results from two demonstration projects. Soc Secur Bull. 2013;73(1):59-71. X-4. [pmid: 23687742].
53 Camfield P, Camfield C. Transition to adult care for children with chronic neurological disorders. Ann Neurol. Mar. 2011;69(3):437-44. X-6. [pmid: 21391239].
54 Carroll AE, DiMeglio LA, Stein S, et al. Contracting and monitoring relationships for adolescents with type 1 diabetes: a pilot study. Diabetes Technol Ther. May. 2011;13(5):543-9. X-3. [pmid: 21406011].
55 Cheak-Zamora NC, Yang X, Farmer JE, et al. Disparities in transition planning for youth with autism spectrum disorder. Pediatrics. Mar. 2013;131(3):447-54. X-5. [pmid: 23400613].
56 Chi DL. Medical Care Transition Planning and Dental Care Use for Youth with Special Health Care Needs During the Transition from Adolescence to Young Adulthood: A Preliminary Explanatory Model. Matern Child Health J. 2013. Jun. 28. X-5. [pmid: 23812799].
57 Chira P, Nugent L, Miller K, et al. Living Profiles: design of a health media platform for teens with special healthcare needs. J Biomed Inform. Oct. 2010;43(5 Suppl):S9-12. X-6. [pmid: 20937487].
58 Chisanga E. Applying specialist nurse skills to improve epilepsy adolescent transition services. British Journal of Neuroscience Nursing. 2009;5(6):274-7. X-7.
59 Christian CW, Schwarz DF. Child maltreatment and the transition to adult-based medical and mental health care. Pediatrics. Jan. 2011;127(1):139-45. X-4. [pmid: 21149424].
60 Christie CD, Pierre RB. Eliminating vertically-transmitted HIV/AIDS while improving access to treatment and care for women, children and adolescents in Jamaica. West Indian Med J. Jul. 2012;61(4):396-404. X-3. [pmid: 23240475].
61 Clark HB, Koroloff N, Geller J, et al. Research on transition to adulthood: building the evidence base to inform services and supports for youth and young adults with serious mental health disorders. J Behav Health Serv Res. Oct. 2008;35(4):365-72. X-6. [pmid: 18726695].
62 Clayton PE, Cuneo RC, Juul A, et al. Consensus statement on the management of the GH-treated adolescent in the transition to adult care. Eur J Endocrinol. Feb. 2005;152(2):165-70. X-6. [pmid: 15745921].
63 Cohen E, Berry JG, Camacho X, et al. Patterns and costs of health care use of children with medical complexity. Pediatrics. Dec. 2012;130(6):e1463-70. X-3. [pmid: 23184117].
64 Colver AF, Merrick H, Deverill M, et al. Study protocol: Longitudinal study of the transition of young people with complex health needs from child to adult health services. BMC Public Health. Jul. 23. 2013;13(1):675. X-6. [pmid: 23875722].
65 Conway GS. Congenital adrenal hyperplasia: adolescence and transition. Horm Res. Suppl 5. 2007;68:155-7. X-6. [pmid: 18174736].
66 Cooley WC. Providing a primary care medical home for children and youth with cerebral palsy. Pediatrics. Oct. 2004;114(4):1106-13. X-3. [pmid: 15466117].
67 Couriel J. Asthma in adolescence. Paediatr Respir Rev. Mar. 2003;4(1):47-54. X-5. [pmid: 12615032].
68 Cox S. Age-appropriate care. Nurs Stand. Jan. 19-25. 2011;25(20):23. X-6. [pmid: 21329167].
69 Craig SL, Towns S, Bibby H. Moving on from paediatric to adult health care: an initial evaluation of a transition program for young people with cystic fibrosis. Int J Adolesc Med Health. Jul-Sep. 2007;19(3):333-43. X-5. [pmid: 17937150].
70 Cramm JM, Strating MM, Sonneveld HM, et al. The Longitudinal Relationship Between Satisfaction with Transitional Care and Social and Emotional Quality of Life Among Chronically Ill Adolescents. Appl Res Qual Life. 2013;8:481-91. X-5. [pmid: 24058386].
71 Creighton SM, Wood D. Complex gynaecological and urological problems in adolescents: challenges and transition. Postgrad Med J. Jan. 2013;89(1047):34-8. X-3. [pmid: 23043130].
72 Crosier J, Wise LC. Coming of age. Cystic fibrosis--once a childhood disease--makes its way to adulthood. Nurs Manage. Nov. 2001;32(11):30-1. X-6. [pmid: 15129541].
73 Cross KP, Santucci KA. Transitional medicine: will emergency medicine physicians be ready for the growing population of adults with congenital heart disease?. Pediatr Emerg Care. Dec. 2006;22(12):775-81. X-1. [pmid: 17198208].
74 Cuttell K, Hilton D, Drew J. Preparation for transition to adult diabetes services. Paediatr Nurs. Mar. 2005;17(2):28-30. X-4. [pmid: 15793986].
75 Daily DK, Ardinger HH, Holmes GE. Identification and evaluation of mental retardation. Am Fam Physician. Feb. 15. 2000;61(4):1059-67. 70. X-3. [pmid: 10706158].
76 Daly B, Kral MC, Tarazi RA. The role of neuropsychological evaluation in pediatric sickle cell disease. Clin Neuropsychol. Aug. 2011;25(6):903-25. X-3. [pmid: 21563016].
77 Daneman D, Nakhla M. Moving On: Transition of Teens With Type 1 Diabetes to Adult Care. Diabetes Spectrum 2011. Winter. 2011;24(1):14-8. X-6.
78 Davies MC. Lost in transition: the needs of adolescents with Turner syndrome. BJOG. Jan. 2010;117(2):134-6. X-6. [pmid: 20002393].
79 Davies PS, Rupp K. An overview of the National Survey of SSI Children and Families and related products. Soc Secur Bull. 2005;66(2):7-20. X-3. [pmid: 16878425].
80 Davis E, Barnhill LJ, Saeed SA. Treatment models for treating patients with combined mental illness and developmental disability. Psychiatr Q. Sep. 2008;79(3):205-23. X-3. [pmid: 18726155].
81 Davis JT. Thoughts from the transition zone. N Engl J Med. Jul. 20. 2006;355(3):235-6. X-3. [pmid: 16855262].
82 Davis M, Koroloff N, Johnsen M. Social network analysis of child and adult interorganizational connections. Psychiatr Rehabil J. Winter. 2012;35(3):265-72. X-4, X-5. [pmid: 22246126].
83 De Sanctis V, Soliman A, Mohamed Y. Reproductive health in young male adults with chronic diseases in childhood. Pediatr Endocrinol Rev. Mar-Apr. 2013;10(3):284-96. X-3. [pmid: 23724436].
84 DeBell D, Carter R. Impact of transition on public health in Ukraine: case study of the HIV/AIDS epidemic. BMJ. Jul. 23. 2005;331(7510):216-9. X-4. [pmid: 16037461].
85 Dellon ES, Jones PD, Martin NB, et al. Health-care transition from pediatric to adult-focused gastroenterology in patients with eosinophilic esophagitis. Dis Esophagus. Jan. 2013;26(1):7-13. X-6. [pmid: 22309247].
86 Dicianno BE, Fairman AD, Juengst SB, et al. Using the spina bifida life course model in clinical practice: an interdisciplinary approach. Pediatr Clin North Am. Aug. 2010;57(4):945-57. X-6. [pmid: 20883884].
87 Dimitropoulos G, Tran AF, Agarwal P, et al. Challenges in making the transition between pediatric and adult eating disorder programs: a qualitative study from the perspective of service providers. Eat Disord. 2013;21(1):1-15. X-5. [pmid: 23241086].
88 Donkervoort M, Wiegerink DJ, van Meeteren J, et al. Transition to adulthood: validation of the Rotterdam Transition Profile for young adults with cerebral palsy and normal intelligence. Dev Med Child Neurol. Jan. 2009;51(1):53-62. X-4. [pmid: 19021680].
89 Douglass LM. Introduction: Transitioning care for adults with Lennox-Gastaut syndrome: challenges and promises. Epilepsia. Aug. Suppl 5. 2011;52:1-2. X-6. [pmid: 21790559].
90 Doyle LW, Anderson PJ. Adult outcome of extremely preterm infants. Pediatrics. Aug. 2010;126(2):342-51. X-3. [pmid: 20679313].
91 Doyle M, Siegel R, Supe K. Stages of change and transitioning for adolescent patients with obesity and hypertension. Adv Chronic Kidney Dis. Oct. 2006;13(4):386-93. X-6. [pmid: 17045224].
92 Drell M. Innovations: Child & adolescent psychiatry: “Sweet are the uses of adversity”: a transition program for children discharged from an inpatient unit. Psychiatr Serv. Jan. 2006;57(1):31-3. X-3. [pmid: 16403727].
93 Dudman L, Rapley P, Wilson S. Development of a transition readiness scale for young adults with cystic fibrosis: face and conten validity. Neonatal, Paediatric & Child Health Nursing. 2011;14(2):9-13. X-5.
94 Dugueperoux I, Tamalet A, Sermet-Gaudelus I, et al. Clinical changes of patients with cystic fibrosis during transition from pediatric to adult care. J Adolesc Health. Nov. 2008;43(5):459-65. X-5. [pmid: 18848674].
95 Dupuis F. Modelisation systemique de la transition pour des familles ayant un adolescent atteint de fibrose kystique en phase pre-transfert vers l'establissement adulte. Universite de Montreal (Canada). 2007. X-7.
96 Dupuis F, Duhamel F, Gendron S. Transitioning care of an adolescent with cystic fibrosis: development of systemic hypothesis between parents, adolescents, and health care professionals. J Fam Nurs. Aug. 2011;17(3):291-311. X-3. [pmid: 21813812].
97 Ellingford C. Short report: refocusing transition clinics. Paediatr Nurs. Jul. 2006;18(6):37. X-6. [pmid: 16881503].
98 Evans J, McDougall J, Baldwin P. An evaluation of the “Youth en Route” program. Phys Occup Ther Pediatr. 2006;26(4):63-87. X-4. [pmid: 17135070].
99 Fair CD, Sullivan K, Dizney R, et al. “It's like losing a part of my family”: transition expectations of adolescents living with perinatally acquired HIV and their guardians. AIDS Patient Care STDS. Jul. 2012;26(7):423-9. X-5. [pmid: 22686235].
100 Fair CD, Sullivan K, Gatto A. Indicators of transition success for youth living with HIV: perspectives of pediatric and adult infectious disease care providers. AIDS Care. Aug. 2011;23(8):965-70. X-5. [pmid: 21390882].
101 Fegran L, C, Uhrenfeldt L, et al. Adolescents' and young adults' transition experiences when transferring from paediatric to adult care: A qualitative metasynthesis. International Journal of Nursing Studies. 2014;51(1):123-35. X-6. [pmid: 23490470].
102 Fernandes SM, Landzberg MJ, Fishman LN, et al. Clinician perceptions of transition of patients with pediatric-onset chronic disease to adult medical care: Comparing a pediatric facility integrated within an adult institution with a free-standing pediatric hospital. International Journal of Child and Adolescent Health. 2013-04-09. 2012;5(3):281-9. 2013-05161-005. X-7.
103 Ferris ME, Ferris MT, Viall C, et al. The self-management and transition to adulthood program “UNC STARX”: Instruments and lessons from the field. International Journal of Child and Adolescent Health. 2013-10-17. 2013;6(2):137-47. 2013-27562-002. X-7.
104 Ferris ME, Harward DH, Bickford K, et al. A clinical tool to measure the components of health-care transition from pediatric care to adult care: the UNC TR(x)ANSITION scale. Ren Fail. 2012;34(6):744-53. X-5. [pmid: 22583152].
105 Ferris ME, Wood D, Ferris MT, et al. Toward evidence-based health care transition: The Health Care Transition Research Consortium. Int J Child Adolesc Health. 2010;3(4):479-86. X-6.
106 Ferro MA. Adolescents and young adults with physical illness: a comparative study of psychological distress. Acta Paediatr. Jan. 2014;103(1):e32-7. X-3. [pmid: 24117721].
107 Flume PA, Anderson DL, Hardy KK, et al. Transition programs in cystic fibrosis centers: perceptions of pediatric and adult program directors. Pediatr Pulmonol. Jun. 2001;31(6):443-50. X-5. [pmid: 11389577].
108 Forcier M, Ahlm S, Boudos R, et al. A hospital-wide initiative to support medically complex adolescents and young adult's transition experience: The process of a systems approach to transition in a tertiary care setting. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):561-74. X-7.
109 Forsyth RJ, Kelly TP, Wicks B, et al. ‘Must try harder?’: a family empowerment intervention for acquired brain injury. Pediatr Rehabil. Apr-Jun. 2005;8(2):140-3. X-3. [pmid: 16089254].
110 Foster C, Waelbrouck A, Peltier A. Adolescents and HIV infection. Curr Opin HIV AIDS. Sep. 2007;2(5):431-6. X-6. [pmid: 19372923].
111 Fredericks EM, Dore-Stites D, Well A, et al. Assessment of transition readiness skills and adherence in pediatric liver transplant recipients. Pediatr Transplant. Dec. 2010;14(8):944-53. X-5. [pmid: 20598086].
112 Freed GL, Hudson EJ. Transitioning children with chronic diseases to adult care: current knowledge, practices, and directions. J Pediatr. Jun. 2006;148(6):824-7. X-6. [pmid: 16769396].
113 Friedman S, Chen C, Chapman JS, et al. Neurodevelopmental outcomes of congenital diaphragmatic hernia survivors followed in a multidisciplinary clinic at ages 1 and 3. J Pediatr Surg. Jun. 2008;43(6):1035-43. X-3. [pmid: 18558179].
114 Frimberger D, Cheng E, Kropp BP. The current management of the neurogenic bladder in children with spina bifida. Pediatr Clin North Am. Aug. 2012;59(4):757-67. X-3. [pmid: 22857827].
115 Frisch D, Msall ME. Health, functioning, and participation of adolescents and adults with cerebral palsy: a review of outcomes research. Dev Disabil Res Rev. Aug. 2013;18(1):84-94. X-3, X-4. [pmid: 23949832].
116 Gall C, Kingsnorth S, Healy H. Growing up ready: a shared management approach. Phys Occup Ther Pediatr. 2006;26(4):47-62. X-4. [pmid: 17135069].
117 Garvey KC, Finkelstein JA, Laffel LM, et al. Transition experiences and health care utilization among young adults with type 1 diabetes. Patient Prefer Adherence. 2013;7:761-9. X-5. [pmid: 23990711].
118 Geerts E, van de Wiel H, Tamminga R. A pilot study on the effects of the transition of paediatric to adult health care in patients with haemophilia and in their parents: patient and parent worries, parental illness-related distress and health-related Quality of Life. Haemophilia. Sep. 2008;14(5):1007-13. X-3. [pmid: 18624704].
119 Gelder C. Care of adolescents in transition. Practice Nursing. 2009;20(9):444-8. X-3.
120 Gilmer TP, Ojeda VD, Fawley-King K, et al. Change in mental health service use after offering youth-specific versus adult programs to transition-age youths. Psychiatr Serv. Jun. 2012;63(6):592-6. X-5. [pmid: 22422015].
121 Glader LJ, Palfrey JS. Care of the child assisted by technology. Pediatr Rev. Nov. 2009;30(11):439-44. quiz 45. X-3. [pmid: 19884284].
122 Goldstein SL, Gerson AC, Goldman CW, et al. Quality of life for children with chronic kidney disease. Semin Nephrol. Mar. 2006;26(2):114-7. X-3. [pmid: 16530604].
123 Goldstone AP, Holland AJ, Hauffa BP, et al. Recommendations for the diagnosis and management of Prader-Willi syndrome. J Clin Endocrinol Metab. Nov. 2008;93(11):4183-97. X-6. [pmid: 18697869].
124 Gupta P. Caring for a teen with congenital heart disease. Pediatr Clin North Am. Feb. 2014;61(1):207-28. X-6. [pmid: 24267466].
125 Gurvitz MZ, Inkelas M, Lee M, et al. Changes in hospitalization patterns among patients with congenital heart disease during the transition from adolescence to adulthood. J Am Coll Cardiol. Feb. 27. 2007;49(8):875-82. X-3, X-5. [pmid: 17320746].
126 Haber MG, Karpur A, Deschenes N, et al. Predicting improvement of transitioning young people in the partnerships for youth transition initiative: findings from a multisite demonstration. J Behav Health Serv Res. Oct. 2008;35(4):488-513. X-4. [pmid: 18636333].
127 Hagenfeldt KB. Congenital adrenal hyperplasia due to 21-hydroxylase deficiency--the adult woman. Growth Horm IGF Res. Jun. Suppl A. 2004;14:S67-71. X-3. [pmid: 15135781].
128 Hall J, Starrett B. Assessing the health care needs of Kansas' young adults with disabilities. Kans Nurse. Aug. 2007;82(7):5-7. X-3, X-5. [pmid: 17902555].
129 Hamdani Y, Jetha A, Norman C. Systems thinking perspectives applied to healthcare transition for youth with disabilities: a paradigm shift for practice, policy and research. Child Care Health Dev. Nov. 2011;37(6):806-14. X-6. [pmid: 22007980].
130 Hanna KM. A framework for the youth with type 1 diabetes during the emerging adulthood transition. Nurs Outlook. Nov-Dec. 2012;60(6):401-10. X-6. [pmid: 22226223].
131 Harden PN, Nadine P. Pediatric to adult transition: a personal experience. Prog Transplant. Dec. 2006;16(4):324-8. X-6. [pmid: 17183939].
132 Harris D. Children with complex needs are overlooked in transition… Art & science, January 14. Nursing Standard. 2009;23(21):32-3. X-3.
133 Harris KM, Gordon-Larsen P, Chantala K, et al. Longitudinal trends in race/ethnic disparities in leading health indicators from adolescence to young adulthood. Arch Pediatr Adolesc Med. Jan. 2006;160(1):74-81. X-3. [pmid: 16389215].
134 Heflinger CA, Hoffman C. Transition age youth in publicly funded systems: identifying high-risk youth for policy planning and improved service delivery. J Behav Health Serv Res. Oct. 2008;35(4):390-401. X-4. [pmid: 17187298].
135 Helgeson VS, Palladino DK, Reynolds KA, et al. Relationships and Health Among Emerging Adults With and Without Type 1 Diabetes. Health Psychol. 2013. Aug. 5. X-3. [pmid: 23914816].
136 Hellstedt LF. Transitional care issues influencing access to health care: employability and insurability. Nurs Clin North Am. Dec. 2004;39(4):741-53. X-4. [pmid: 15561157].
137 Hemker BG, Brousseau DC, Yan K, et al. When children with sickle-cell disease become adults: lack of outpatient care leads to increased use of the emergency department. Am J Hematol. Oct. 2011;86(10):863-5. X-3. [pmid: 21815184].
138 Hergenroeder AC. The transition into adulthood for children and youth with special health care needs. Tex Med. Feb. 2002;98(2):51-8. X-6. [pmid: 11862893].
139 Hersh A, von Scheven E, Yelin E. Adult outcomes of childhood-onset rheumatic diseases. Nat Rev Rheumatol. May. 2011;7(5):290-5. X-5. [pmid: 21487383].
140 Hewer SC, Tyrrell J. Cystic fibrosis and the transition to adult health services. Arch Dis Child. Oct. 2008;93(10):817-21. X-6. [pmid: 18809702].
141 Hilderson D, Corstjens F, Moons P, et al. Adolescents with juvenile idiopathic arthritis: who cares after the age of 16?. Clin Exp Rheumatol. Sep-Oct. 2010;28(5):790-7. X-5. [pmid: 20863450].
142 Hilderson D, Eyckmans L, Van der Elst K, et al. Transfer from paediatric rheumatology to the adult rheumatology setting: experiences and expectations of young adults with juvenile idiopathic arthritis. Clin Rheumatol. May. 2013;32(5):575-83. X-5. [pmid: 23238606].
143 Hilderson D, Saidi AS, Van Deyk K, et al. Attitude toward and current practice of transfer and transition of adolescents with congenital heart disease in the United States of America and Europe. Pediatr Cardiol. Aug. 2009;30(6):786-93. X-5. [pmid: 19365651].
144 Hilderson D, Westhovens R, Wouters C, et al. Rationale, design and baseline data of a mixed methods study examining the clinical impact of a brief transition programme for young people with juvenile idiopathic arthritis: the DON'T RETARD project. BMJ Open. 2013;3(12):e003591. X-5. [pmid: 24302502].
145 Hilliard ME, Perlus JG, Clark LM, et al. Perspectives from Before and After the Pediatric to Adult Care Transition: A Mixed-Methods Study in Type 1 Diabetes. Diabetes Care. 2013. Oct. 2. X-5. [pmid: 24089544].
146 Hink H, Schellhase D. Transitioning families to adult cystic fibrosis care. J Spec Pediatr Nurs. Oct. 2006;11(4):260-3. X-6. [pmid: 16999750].
147 Hodson ME. Treatment of cystic fibrosis in the adult. Respiration. 2000;67(6):595-607. X-6. [pmid: 11124641].
148 Hoek W, Marko M, Fogel J, et al. Randomized controlled trial of primary care physician motivational interviewing versus brief advice to engage adolescents with an Internet-based depression prevention intervention: 6-month outcomes and predictors of improvement. Transl Res. Dec. 2011;158(6):315-25. X-3. [pmid: 22061038].
149 Homer CJ, Cooley WC, Strickland B. Medical home 2009: what it is, where we were, and where we are today. Pediatr Ann. Sep. 2009;38(9):483-90. X-3. [pmid: 19772234].
150 Hong DS. Child and adolescent psychiatrists are often tasked with the challenge of treating patients in various contexts. J Am Acad Child Adolesc Psychiatry. Sep. 2013;52(9):885-6. X-6. [pmid: 23972687].
151 Hosie P, Mair R. Primary Care 2011. J Fam Health Care. Jul-Aug. 2011;21(4):38-41. X-2, X-3. [pmid: 21980695].
152 Hovish K, Weaver T, Islam Z, et al. Transition experiences of mental health service users, parents, and professionals in the United Kingdom: a qualitative study. Psychiatr Rehabil J. Winter. 2012;35(3):251-7. X-5. [pmid: 22246124].
153 Hower H, Case BG, Hoeppner B, et al. Use of mental health services in transition age youth with bipolar disorder. J Psychiatr Pract. Nov. 2013;19(6):464-76. X-5. [pmid: 24241500].
154 Hughes IA. Congenital adrenal hyperplasia: transitional care. Growth Horm IGF Res. Jun. Suppl A. 2004;14:S60-6. X-6. [pmid: 15135780].
155 Hullmann SE, Chalmers LJ, Wisniewski AB. Transition from pediatric to adult care for adolescents and young adults with a disorder of sex development. J Pediatr Adolesc Gynecol. Apr. 2012;25(2):155-7. X-6. [pmid: 22530227].
156 Hummel TZ, Tak E, Maurice-Stam H, et al. Psychosocial developmental trajectory of adolescents with inflammatory bowel disease. J Pediatr Gastroenterol Nutr. Aug. 2013;57(2):219-24. X-3. [pmid: 23880627].
157 Hunt S, Sharma N. Pediatric to adult-care transitions in childhood-onset chronic disease: hospitalist perspectives. J Hosp Med. Nov. 2013;8(11):627-30. X-1. [pmid: 24124077].
158 Iannelli-Madigan G. Transitioning the adolescent with type 1 diabetes mellitus. J Pediatr Nurs. Oct. 2012;27(5):602-4. X-6. [pmid: 22819877].
159 Iles N, Lowton K. Young people with cystic fibrosis' concerns for their future: when and how should concerns be addressed, and by whom?. J Interprof Care. Aug. 2008;22(4):436-8. X-5. [pmid: 18800285].
160 Iles N, Lowton K. What is the perceived nature of parental care and support for young people with cystic fibrosis as they enter adult health services?. Health Soc Care Community. Jan. 2010;18(1):21-9. X-4, X-5. [pmid: 19637994].
161 Irvine T, Srinivasan R, Casson DH, et al. Assessing the value of a pre-transfer meeting in IBD transition services. Gastrointestinal Nursing. 2010;8(7):19. X-5.
162 Ishizaki Y, Maru M, Higashino H, et al. The transition of adult patients with childhood-onset chronic diseases from pediatric to adult healthcare systems: a survey of the perceptions of Japanese pediatricians and child health nurses. Biopsychosoc Med. 2012;6:8. X-5. [pmid: 22433283].
163 Iyer A, Appleton R. Transitional services for adolescents with epilepsy in the U.K.: a survey. Seizure. Jul. 2013;22(6):433-7. X-5. [pmid: 23498777].
164 Jackett JM. Transition and beyond for individuals with autism spectrum disorders (ASD): a New Jersey case study of the adult service sector, its inherent shortcomings, and hope for the future. Seton Hall Law Rev. 2010;40(4):1733-74. X-3, X-4. [pmid: 21280391].
165 Jackson KE. 157. Health Care Transition Guidance For Youth With Cerebral Palsy:An Analysis Of The National Survey Of Children With Special Health Care Needs. Journal of Adolescent Health. 2012;50(2):S88-9. X-5.
166 Jedeloo S, van Staa A, Latour JM, et al. Preferences for health care and self-management among Dutch adolescents with chronic conditions: a Q-methodological investigation. Int J Nurs Stud. May. 2010;47(5):593-603. X-3. [pmid: 19900675].
167 Jermyn V. “You can't stay here!” Transition from paediatric to adult health care management for liver transplant recipients. Transplant Journal of Australasia. 2013;22(3):15-8. X-7.
168 Jones BL, Parker-Raley J, Barczyk A. Adolescent cancer survivors: identity paradox and the need to belong. Qual Health Res. Aug. 2011;21(8):1033-40. X-2. [pmid: 21447805].
169 Jones SE, Hamilton S. The missing link: paediatric to adult transition in diabetes services. Br J Nurs. Jul. 10-23. 2008;17(13):842-7. X-6. [pmid: 18856147].
170 Jorgensen S. Lost in transition. Learning Disability Practice. 2008;11(7):30-1. X-6.
171 Kane DJ, Zotti ME, Rosenberg D. Factors associated with health care access for Mississippi children with special health care needs. Matern Child Health J. Jun. 2005;9(2 Suppl):S23-31. X-3. [pmid: 15973475].
172 Karan OC, DonAroma P, Bruder MB, et al. Transitional assessment model for students with severe and/or multiple disabilities: competency-based community assessment. Intellect Dev Disabil. Oct. 2010;48(5):387-92. X-3, X-4, X-6. [pmid: 20973701].
173 Karas DJ, Costain G, Chow EW, et al. Perceived burden and neuropsychiatric morbidities in adults with 22q11.2 deletion syndrome. J Intellect Disabil Res. Feb. 2014;58(2):198-210. X-1. [pmid: 23106770].
174 Kaufman M. Role of adolescent development in the transition process. Prog Transplant. Dec. 2006;16(4):286-90. X-4. [pmid: 17183934].
175 Kaufman M. Transition of cognitively delayed adolescent organ transplant recipients to adult care. Pediatr Transplant. Jun. 2006;10(4):413-7. X-6. [pmid: 16712597].
176 Kennedy A, Sawyer S. Transition from pediatric to adult services: are we getting it right?. Curr Opin Pediatr. Aug. 2008;20(4):403-9. X-6. [pmid: 18622194].
177 Khan A, Baheerathan A, Hussain N, et al. Transition of children with epilepsies to adult care. Acta Paediatr. Mar. 2013;102(3):216-21. X-6. [pmid: 23190350].
178 Kime N. ‘Join us on our journey’: exploring the experiences of children and young people with type 1 diabetes and their parents. Practical Diabetes. 2014;31(1):24-8. X-5.
179 Kingsnorth S, Gall C, Beayni S, et al. Parents as transition experts? Qualitative findings from a pilot parent-led peer support group. Child Care Health Dev. Nov. 2011;37(6):833-40. X-1. [pmid: 22007983].
180 Kirk S. Transitions in the lives of young people with complex healthcare needs. Child Care Health Dev. Sep. 2008;34(5):567-75. X-5. [pmid: 18796049].
181 Kirkpatrick JN, Kim YY, Kaufman BD. Ethics priorities in adult congenital heart disease. Prog Cardiovasc Dis. Nov-Dec. 2012;55(3):266-73 e3. X-6. [pmid: 23217430].
182 Klaas S, Hickey K. Transition to adult care. SCI Nurs. Fall. 2001;18(3):158-60. X-6. [pmid: 12503463].
183 Knapp C, Huang IC, Hinojosa M, et al. Assessing the congruence of transition preparedness as reported by parents and their adolescents with special health care needs. Matern Child Health J. Feb. 2013;17(2):352-8. X-5. [pmid: 22415813].
184 Ko B, McEnery G. The needs of physically disabled young people during transition to adult services. Child Care Health Dev. Jul. 2004;30(4):317-23. X-5. [pmid: 15191421].
185 Kollipara S, Kaufman FR. Transition of diabetes care from pediatrics to adulthood. School Nurse News. Jan. 2008;25(1):27-9. X-6. [pmid: 18236837].
186 Kossoff EH, Henry BJ, Cervenka MC. Transitioning pediatric patients receiving ketogenic diets for epilepsy into adulthood. Seizure. Jul. 2013;22(6):487-9. X-5. [pmid: 23571095].
187 Kripke C, Giammona M, Fox A, et al. The CART model: Organized systems of care for transition age youth and adults with developmental disabilities. Int J Child Adolesc Health. 2010;3(4):473-7. X-6.
188 Kruse B, Riepe FG, Krone N, et al. Congenital adrenal hyperplasia - how to improve the transition from adolescence to adult life. Exp Clin Endocrinol Diabetes. Jul. 2004;112(7):343-55. X-6. [pmid: 15239019].
189 Kuchenbuch M, Chemaly N, Chiron C, et al. Transition and transfer from pediatric to adult health care in epilepsy: a families' survey on Dravet syndrome. Epilepsy Behav. Oct. 2013;29(1):161-5. X-5. [pmid: 23973640].
190 Ladores S. An evolutionary concept analysis of healthcare transition among adolescents with chronic illness. Southern Online Journal of Nursing Research. 2008;8(2):2. X-6.
191 Latzman RD, Majumdar S, Bigelow C, et al. Transitioning to adult care among adolescents with sickle cell disease: A transitioning clinic based on patient and caregiver concerns and needs. Int J Child Adolesc Health. 2010;3(4):537-45. X-7.
192 Lawson EF, Hersh AO, Applebaum MA, et al. Self-management skills in adolescents with chronic rheumatic disease: A cross-sectional survey. Pediatr Rheumatol Online J. 2011;9(1):35. X-3. [pmid: 22145642].
193 Lawson V. I wasn't the only one. Ment Health Today. Jul-Aug. 2003:34-6. X-3. [pmid: 14625919].
194 Lee PJ. Growing older: the adult metabolic clinic. J Inherit Metab Dis. May. 2002;25(3):252-60. X-3. [pmid: 12137234].
195 Lefebvre H, Levert MJ. The needs experienced by individuals and their loved ones following a traumatic brain injury. J Trauma Nurs. Oct-Dec. 2012;19(4):197-207. X-1. [pmid: 23222398].
196 Lemacks J, Fowles K, Mateus A, et al. Insights from parents about caring for a child with birth defects. Int J Environ Res Public Health. Aug. 2013;10(8):3465-82. X-6. [pmid: 23965922].
197 Leonard BJ, Garwick A, Adwan JZ. Adolescents' perceptions of parental roles and involvement in diabetes management. J Pediatr Nurs. Dec. 2005;20(6):405-14. X-3. [pmid: 16298281].
198 Lesch W, Specht K, Lux A, et al. Disease-specific knowledge and information preferences of young patients with congenital heart disease. Cardiol Young. Apr. 2013;29:1-10. X-3. [pmid: 23628281].
199 Lewis SA, Noyes J. Effective process or dangerous precipice: qualitative comparative embedded case study with young people with epilepsy and their parents during transition from children's to adult services. BMC Pediatr. Oct. 16. 2013;13(1):169. X-5. [pmid: 24131769].
200 Lewis SA, Noyes J, Mackereth S. Knowledge and information needs of young people with epilepsy and their parents: Mixed-method systematic review. BMC Pediatr. 2010;10:103. X-3. [pmid: 21194484].
201 Libby R. Principles of health care financing. Pediatrics. Nov. 2010;126(5):1018-21. X-2, X-3. [pmid: 20974786].
202 Lindgren E, Soderberg S, Skar L. The gap in transition between child and adolescent psychiatry and general adult psychiatry. J Child Adolesc Psychiatr Nurs. May. 2013;26(2):103-9. X-5. [pmid: 23607821].
203 Lineham K. Caring for young people with chronic illness: a case study. Paediatr Nurs. Feb. 2010;22(1):20-3. X-4. [pmid: 20302060].
204 LoCasale-Crouch J, Johnson B. Transition from pediatric to adult medical care. Adv Chronic Kidney Dis. Oct. 2005;12(4):412-7. X-1. [pmid: 16198281].
205 Looman WS, Lindeke LL. Children and youth with special health care needs: partnering with families for effective advocacy. J Pediatr Health Care. Mar-Apr. 2008;22(2):134-6. X-3. [pmid: 18294584].
206 Lotstein DS, McPherson M, Strickland B, et al. Transition planning for youth with special health care needs: results from the National Survey of Children with Special Health Care Needs. Pediatrics. Jun. 2005;115(6):1562-8. X-5. [pmid: 15930217].
207 Lotstein DS, Seid M, Klingensmith G, et al. Transition from pediatric to adult care for youth diagnosed with type 1 diabetes in adolescence. Pediatrics. Apr. 2013;131(4):e1062-70. X-5. [pmid: 23530167].
208 Lubetsky MJ, Handen BL, Lubetsky M, et al. Systems of care for individuals with autism spectrum disorder and serious behavioral disturbance through the lifespan. Child Adolesc Psychiatr Clin N Am. Jan. 2014;23(1):97-110. X-6. [pmid: 24231170].
209 Lundin CS, Danielson E, Ohrn I. Handling the transition of adolescents with diabetes: participant observations and interviews with care providers in paediatric and adult diabetes outpatient clinics. Int J Integr Care. 2007;7:e05. X-5. [pmid: 17377641].
210 Luyckx K, Goossens E, Van Damme C, et al. Identity formation in adolescents with congenital cardiac disease: a forgotten issue in the transition to adulthood. Cardiol Young. Aug. 2011;21(4):411-20. X-3, X-4. [pmid: 21406136].
211 Lyons SK, Libman IM, Sperling MA. Clinical review: Diabetes in the adolescent: transitional issues. J Clin Endocrinol Metab. Dec. 2013;98(12):4639-45. X-8. [pmid: 24152689].
212 Macdonald S, McLaughlin S, Levey E, et al. One family's journey: Medical Home and the network of supports it offers children and youth with special healthcare needs: the transition process continues. Exceptional Parent. 2008;38(5):60-3. X-6.
213 Macdonald S, Sagerman PJ, Boyd L, et al. One family's journey: Medical Home and the network of supports [sic] it offers children and youth with special healthcare needs: the transition process starts early… part seven. Exceptional Parent. 2008;38(4):57-61. X-6.
214 Majnemer A, Mazer B. New directions in the outcome evaluation of children with cerebral palsy. Semin Pediatr Neurol. Mar. 2004;11(1):11-7. X-3. [pmid: 15132249].
215 Mandarino K. Transitional-Age Youths: Barriers to Accessing Adult Mental Health Services and the Changing Definition of Adolescence. Journal of Human Behavior in the Social Environment. 2014;24(4):462-74. X-7.
216 Mandelco B, Clark L, Freeborn D, et al. Overview: transition to adulthood: challenges for parents and youth with disabilities. Communicating Nursing Research. 2010;43:194. X-7.
217 Manzur AY, Muntoni F. Diagnosis and new treatments in muscular dystrophies. J Neurol Neurosurg Psychiatry. Jul. 2009;80(7):706-14. X-6. [pmid: 19531685].
218 Manzur AY, Muntoni F. Diagnosis and new treatments in muscular dystrophies. Postgrad Med J. Nov. 2009;85(1009):622-30. X-6. [pmid: 19892898].
219 Marcer H, Finlay F, Baverstock A. ADHD and transition to adult services--the experience of community paediatricians. Child Care Health Dev. Sep. 2008;34(5):564-6. X-5. [pmid: 18796048].
220 Markowitz JT, Laffel LM. Transitions in care: support group for young adults with Type 1 diabetes. Diabet Med. Apr. 2012;29(4):522-5. X-5. [pmid: 22150392].
221 Marshall M, Carter B, Rose K, et al. Living with type 1 diabetes: perceptions of children and their parents. J Clin Nurs. Jun. 2009;18(12):1703-10. X-3. [pmid: 19646116].
222 Martin AB, Crawford S, Probst JC, et al. Medical homes for children with special health care needs: a program evaluation. J Health Care Poor Underserved. Nov. 2007;18(4):916-30. X-3. [pmid: 17982215].
223 Matlow AG, Wright JG, Zimmerman B, et al. How can the principles of complexity science be applied to improve the coordination of care for complex pediatric patients?. Qual Saf Health Care. Apr. 2006;15(2):85-8. X-3. [pmid: 16585105].
224 Maunder EZ. The challenge of transitional care for young people with life-limiting illness. Br J Nurs. May. 27. Jun. 9. 2004;13(10):594-6. X-6. [pmid: 15215714].
225 McAllister JW, Presler E, Cooley WC. Practice-based care coordination: a medical home essential. Pediatrics. Sep. 2007;120(3):e723-33. X-3. [pmid: 17766512].
226 McClannahan LE, MacDuff GS, Krantz PJ. Behavior analysis and intervention for adults with autism. Behav Modif. Jan. 2002;26(1):9-26. X-4. [pmid: 11799656].
227 McCurdy C, DiCenso A, Boblin S, et al. There to here: young adult patients' perceptions of the process of transition from pediatric to adult transplant care. Prog Transplant. Dec. 2006;16(4):309-16. X-5. [pmid: 17183937].
228 McDonagh JE. Transition of care from paediatric to adult rheumatology. Arch Dis Child. Sep. 2007;92(9):802-7. X-6. [pmid: 17715444].
229 McDonagh JE. Young people first, juvenile idiopathic arthritis second: transitional care in rheumatology. Arthritis Rheum. Aug. 15. 2008;59(8):1162-70. X-6. [pmid: 18668608].
230 McDonagh JE, Kaufman M. Transition from pediatric to adult care after solid organ transplantation. Curr Opin Organ Transplant. Oct. 2009;14(5):526-32. X-6. [pmid: 19617823].
231 McDonagh JE, Kelly DA. Transitioning care of the pediatric recipient to adult caregivers. Pediatr Clin North Am. Dec. 2003;50(6):1561-83. xi. xii. X-6. [pmid: 14710793].
232 McGrew JH, Danner M. Evaluation of an intensive case management program for transition age youth and its transition to assertive community treatment. American Journal of Psychiatric Rehabilitation. 2009;12(3):278-94. X-3.
233 McLaughlin S, Bowering N, Crosby B, et al. Health care transition for adolescents with special health care needs: a report on the development and use of a clinical transition service. R I Med J (2013). 2013;96(4):25-7. X-5. [pmid: 23641448].
234 McLaughlin SE, Diener-West M, Indurkhya A, et al. Improving transition from pediatric to adult cystic fibrosis care: lessons from a national survey of current practices. Pediatrics. May. 2008;121(5):e1160-6. X-5. [pmid: 18450860].
235 McMillan JA. Growing pains: prepared for transition with nowhere to go. Contemporary Pediatrics. 2009;26(12):6. X-3.
236 McMillen JC, Raghavan R. Pediatric to adult mental health service use of young people leaving the foster care system. J Adolesc Health. Jan. 2009;44(1):7-13. X-5. [pmid: 19101453].
237 McNamara N, McNicholas F, Ford T, et al. Transition from child and adolescent to adult mental health services in the Republic of Ireland: an investigation of process and operational practice. Early Interv Psychiatry. 2013. Jul. 4. X-5. [pmid: 23826636].
238 McPherson M, Thaniel L, Minniti CP. Transition of patients with sickle cell disease from pediatric to adult care: Assessing patient readiness. Pediatr Blood Cancer. Jul. 2009;52(7):838-41. X-5. [pmid: 19229973].
239 McPherson M, Weissman G, Strickland BB, et al. Implementing community-based systems of services for children and youths with special health care needs: how well are we doing?. Pediatrics. May. 2004;113(5 Suppl):1538-44. X-3. [pmid: 15121923].
240 Mennito S. Resident preferences for a curriculum in healthcare transitions for young adults. South Med J. Sep. 2012;105(9):462-6. X-1. [pmid: 22948324].
241 Michaud PA, Suris JC, Viner R. The adolescent with a chronic condition. Part II: healthcare provision. Arch Dis Child. Oct. 2004;89(10):943-9. X-3. [pmid: 15383439].
242 Milbrath C. Caring for an underserved population: Helping pediatric patients with disabilities transition to adulthood. Creat Nurs. 2008;14(2):66-9. X-6. [pmid: 18655515].
243 Miles K, Edwards S, Clapson M. Transition from paediatric to adult services: experiences of HIV-positive adolescents. AIDS Care. Apr. 2004;16(3):305-14. X-5. [pmid: 15203424].
244 Miller D, MacDonald D. Management of pediatric patients with chronic kidney disease. Pediatr Nurs. Mar-Apr. 2006;32(2):128-34. quiz 35. X-3. [pmid: 16719422].
245 Miller VA, Harris D. Measuring children's decision-making involvement regarding chronic illness management. J Pediatr Psychol. Apr. 2012;37(3):292-306. X-3. [pmid: 22138318].
246 Mills J, Cutajar P, Jones J, et al. Ensuring the successful transition of adolescents to adult services. Learning Disability Practice. 2013;16(6):26-8. X-5.
247 Moons P, De Geest S, Budts W. Comprehensive care for adults with congenital heart disease: expanding roles for nurses. Eur J Cardiovasc Nurs. Feb. 2002;1(1):23-8. X-6. [pmid: 14622863].
248 Moorthy LN, Peterson MG, Hassett AL, et al. Burden of childhood-onset arthritis. Pediatr Rheumatol Online J. 2010;8:20. X-6. [pmid: 20615240].
249 Munson MR, Jaccard J, Smalling SE, et al. Static, dynamic, integrated, and contextualized: a framework for understanding mental health service utilization among young adults. Soc Sci Med. Oct. 2012;75(8):1441-9. X-3. [pmid: 22800921].
250 Musallam K, Cappellini MD, Taher A. Challenges associated with prolonged survival of patients with thalassemia: transitioning from childhood to adulthood. Pediatrics. May. 2008;121(5):e1426-9. X-6. [pmid: 18450884].
251 Mutze U, Roth A, Weigel JF, et al. Transition of young adults with phenylketonuria from pediatric to adult care. J Inherit Metab Dis. Jun. 2011;34(3):701-9. X-5. [pmid: 21305352].
252 Myers CT. Exploring occupational therapy and transitions for young children with special needs. Phys Occup Ther Pediatr. 2006;26(3):73-88. X-3. [pmid: 16966317].
253 Nakhla M, Daneman D, Frank M, et al. Translating transition: a critical review of the diabetes literature. J Pediatr Endocrinol Metab. Jun. 2008;21(6):507-16. X-6. [pmid: 18717235].
254 Neff JM, Clifton H, Park KJ, et al. Identifying children with lifelong chronic conditions for care coordination by using hospital discharge data. Acad Pediatr. Nov-Dec. 2010;10(6):417-23. X-3. [pmid: 21075324].
255 Neu A, Losch-Binder M, Ehehalt S, et al. Follow-up of adolescents with diabetes after transition from paediatric to adult care: results of a 10-year prospective study. Exp Clin Endocrinol Diabetes. Jun. 2010;118(6):353-5. X-5. [pmid: 20140851].
256 Nutt DJ, Fone K, Asherson P, et al. Evidence-based guidelines for management of attention-deficit/hyperactivity disorder in adolescents in transition to adult services and in adults: recommendations from the British Association for Psychopharmacology. J Psychopharmacol. Jan. 2007;21(1):10-41. X-6. [pmid: 17092962].
257 O'Connor KS, Brooks KS, Nysse-Carris KL, et al. Design and operation of the Survey of Adult Transition and Health, 2007. Vital Health Stat 1. Mar. 2011;(52):1-85. X-1. [pmid: 21548442].
258 Oftedahl E, Benedict R, Katcher ML. National survey of children with special health care needs: Wisconsin-specific data. WMJ. 2004;103(5):88-90. X-3. [pmid: 15553573].
259 Okumura MJ, Heisler M, Davis MM, et al. Comfort of general internists and general pediatricians in providing care for young adults with chronic illnesses of childhood. J Gen Intern Med. Oct. 2008;23(10):1621-7. X-5. [pmid: 18661191].
260 Onyeajam DJ, Eke R, Stephens TG, et al. Time to linkage to care and viro-immunologic parameters of individuals diagnosed before and after the 2006 HIV testing recommendations. South Med J. Apr. 2013;106(4):257-66. X-1, X-3. [pmid: 23558414].
261 Oskoui M. Growing up with cerebral palsy: contemporary challenges of healthcare transition. Can J Neurol Sci. Jan. 2012;39(1):23-5. X-6. [pmid: 22384484].
262 Ostlie IL, Dale O, Moller A. From childhood to adult life with juvenile idiopathic arthritis (JIA): a pilot study. Disabil Rehabil. Mar. 30. 2007;29(6):445-52. X-5. [pmid: 17364799].
263 Oswald DP, Bodurtha JN, Willis JH, et al. Underinsurance and key health outcomes for children with special health care needs. Pediatrics. Feb. 2007;119(2):e341-7. X-5. [pmid: 17210727].
264 Owen P, Beskine D. Factors affecting transition of young people with diabetes. Paediatr Nurs. Sep. 2008;20(7):33-8. X-6. [pmid: 18808056].
265 Pacaud D. Editorial commentary. Bridge over troubled water: improving the transition from pediatric to adult care. The pediatric care perspective. Canadian Journal of Diabetes. 2005;29(3):183-4. X-6.
266 Pacaud D, Yale J, Stephure D, et al. Problems in transition from pediatric care to adult care for individuals with diabetes. Canadian Journal of Diabetes. 2005;29(1):13-8. X-5.
267 Pacaud D, Yale JF. Exploring a black hole: Transition from paediatric to adult care services for youth with diabetes. Paediatr Child Health. Jan. 2005;10(1):31-4. X-6. [pmid: 19657443].
268 Pakdeeprom B, In-Iw S, Chintanadilok N, et al. Promoting factors for transition readiness of adolescent chronic illnesses: experiences in Thailand. J Med Assoc Thai. Aug. 2012;95(8):1028-34. X-5. [pmid: 23061306].
269 Palmer J, Glah C, Zelikovsky N, et al. A Collaborative Approach to the Transition of Adolescent Renal Transplant Recipients to Adult Care Providers. Nephrology Nursing Journal. 2011;38(2):200. X-5.
270 Papagianni M, Stanhope R. How should we manage growth hormone deficiency in adolescence? Transition from paediatric to adult care. J Pediatr Endocrinol Metab. Jan. 2003;16(1):23-5. X-6. [pmid: 12585336].
271 Parachuri V, Inglese C. Neurological problems in the adolescent population. Adolesc Med State Art Rev. Apr. 2013;24(1):1-28. X-3, X-6. [pmid: 23705516].
272 Parfitt G. Imroving young person's experience transition: lessons from Wales. Paediatr Nurs. Nov. 2008;20(9):27-30. X-6. [pmid: 19006948].
273 Parr C. Ensuring equity in diabetes care. Independent Nurse. 2012:10. X-3.
274 Patterson D. Promoting successful transition from pediatric to adult-oriented health care. Exceptional Parent. 2004;34(3):56. X-6.
275 Paul M, Ford T, Kramer T, et al. Transfers and transitions between child and adult mental health services. Br J Psychiatry Suppl. Jan. 2013;54:s36-40. X-5. [pmid: 23288500].
276 Pearson GS, Hawke JM, Dundon E, et al. Timely help for troubled youth. Behav Healthc. Mar. 2010;30(3):31-3. X-3. [pmid: 20373689].
277 Pedreira CC, Hameed R, Kanumakala S, et al. Health-care problems of Turner syndrome in the adult woman: a cross sectional study of a Victorian cohort and a case for transition. Intern Med J. Jan. 2006;36(1):54-7. X-1, X-3. [pmid: 16409314].
278 Perry L, Lowe JM, Steinbeck KS, et al. Services doing the best they can: service experiences of young adults with type 1 diabetes mellitus in rural Australia. J Clin Nurs. Jul. 2012;21(13-14):1955-63. X-5. [pmid: 22672458].
279 Petitgout JM, Pelzer DE, McConkey SA, et al. Development of a hospital-based care coordination program for children with special health care needs. J Pediatr Health Care. Nov-Dec. 2013;27(6):419-25. X-5. [pmid: 22575784].
280 Philpott JR. Transitional care in inflammatory bowel disease. Gastroenterol Hepatol (N Y). Jan. 2011;7(1):26-32. X-6. [pmid: 21346849].
281 Pickler L, Kellar-Guenther Y, Goldson E. Barriers to transition to adult care for youth with intellectual disabilities. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):575-84. X-7.
282 Pilnick A, Clegg J, Murphy E, et al. Questioning the answer: questioning style, choice and self-determination in interactions with young people with intellectual disabilities. Sociol Health Illn. Mar. 2010;32(3):415-36. X-4. [pmid: 20415789].
283 Porter JS, Graff JC, Lopez AD, et al. Transition From Pediatric to Adult Care in Sickle Cell Disease: Perspectives on the Family Role. J Pediatr Nurs. 2013. Oct. 16. X-5. [pmid: 24188784].
284 Price C, Corbett S, Dovey-Pearce G. Barriers and facilitators to implementing a transition pathway for adolescents with diabetes: A health professionals perspective. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):489-98. X-7.
285 Price CS, Corbett S, Lewis-Barned N, et al. Implementing a transition pathway in diabetes: a qualitative study of the experiences and suggestions of young people with diabetes. Child Care Health Dev. Nov. 2011;37(6):852-60. X-5. [pmid: 22007985].
286 Punch R, Hyde M, Creed PA. Issues in the school-to-work transition of hard of hearing adolescents. Am Ann Deaf. Spring. 2004;149(1):28-38. X-3, X-4. [pmid: 15332464].
287 Punpanich W, Detels R, Gorbach PM, et al. Understanding the psychosocial needs of HIV-infected children and families: a qualitative study. J Med Assoc Thai. Oct. Suppl 3. 2008;91:S76-84. X-3. [pmid: 19253500].
288 Quinn CT, Rogers ZR, McCavit TL, et al. Improved survival of children and adolescents with sickle cell disease. Blood. Apr. 29. 2010;115(17):3447-52. X-3. [pmid: 20194891].
289 Rasmussen B, Wellard S, Nankervis A. Consumer issues in navigating health care services for type I diabetes. J Clin Nurs. Sep. 2001;10(5):628-34. X-5. [pmid: 11822513].
290 Read N, Schofield A. Autism: are mental health services failing children and parents?. J Fam Health Care. 2010;20(4):120-4. X-3. [pmid: 21053660].
291 Reading R. Lost in transition? Between paediatric and adult services. Child: Care, Health & Development. 2006;32(4):501-2. X-6.
292 Rekate HL. The pediatric neurosurgical patient: the challenge of growing up. Semin Pediatr Neurol. Mar. 2009;16(1):2-8. X-6. [pmid: 19410150].
293 Remorino R, Taylor J. Smoothing things over: the transition from pediatric to adult care for kidney transplant recipients. Prog Transplant. Dec. 2006;16(4):303-8. X-5. [pmid: 17183936].
294 Rideout K. Evaluation of a PNP care coordinator model for hospitalized children, adolescents, and young adults with cystic fibrosis. Pediatr Nurs. Jan-Feb. 2007;33(1):29-35. quiz -6. X-3. [pmid: 17410998].
295 Ritholz MD, Wolpert H, Beste M, et al. Patient-Provider Relationships Across the Transition From Pediatric to Adult Diabetes Care: A Qualitative Study. Diabetes Educ. 2013. Nov. 20. X-5. [pmid: 24258251].
296 Robertson LP, McDonagh JE, Southwood TR, et al. Growing up and moving on. A multicentre UK audit of the transfer of adolescents with juvenile idiopathic arthritis from paediatric to adult centred care. Ann Rheum Dis. Jan. 2006;65(1):74-80. X-5. [pmid: 15994281].
297 Rook M, Rosenthal P. Caring for adults with pediatric liver disease. Curr Gastroenterol Rep. Feb. 2009;11(1):83-9. x-6. [pmid: 19166664].
298 Rosenberg D, Onufer C, Clark G, et al. The need for care coordination among children with special health care needs in Illinois. Matern Child Health J. Jun. 2005;9(2 Suppl):S41-7. X-3. [pmid: 15973478].
299 Ross AC, Camacho-Gonzalez A, Henderson S, et al. The HIV-Infected Adolescent. Curr Infect Dis Rep. Jan. 2010;12(1):63-70. X-6. [pmid: 21308499].
300 Rouse CM. Informing choice or teaching submission to medical authority: a case study of adolescent transitioning for sickle cell patients. Ethn Health. Aug-Oct. 2011;16(4-5):313-25. X-3. [pmid: 21797720].
301 Rubin K. Transitioning the patient with Turner's syndrome from pediatric to adult care. J Pediatr Endocrinol Metab. May. Suppl 3. 2003;16:651-9. X-7. [pmid: 12795368].
302 Rubin KR. Turner syndrome: transition from pediatrics to adulthood. Endocr Pract. Sep. 2008;14(6):775-81. X-6. [pmid: 18996801].
303 Ruck J, Dahan-Oliel N. Adolescence and young adulthood in spina bifida: self-report on care received and readiness for the future. Topics in Spinal Cord Injury Rehabilitation. 2010;16(1):26-37. X-5.
304 Rudy C. When do pediatric patients graduate?. J Pediatr Health Care. Sep-Oct. 2006;20(5):334-5. 58. 60. X-6. [pmid: 16962439].
305 Saidi A, Reiss J, Breitinger P, et al. Web-based learning: Is it an effective method for educating pediatric residents about transition to adult subspecialty congenital heart disease care?. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):585-93. X-7.
306 Sakakibara H, Yoshida H, Takei M, et al. Health management of adults with Turner syndrome: an attempt at multidisciplinary medical care by gynecologists in cooperation with specialists from other fields. J Obstet Gynaecol Res. Jul. 2011;37(7):836-42. X-1. [pmid: 21410832].
307 Samyn M. Optimizing outcomes for pediatric recipients. Liver Transpl. Nov. Suppl 2. 2012;18:S34-8. X-6. [pmid: 22941584].
308 Scal P, Davern M, Ireland M, et al. Transition to adulthood: delays and unmet needs among adolescents and young adults with asthma. J Pediatr. Apr. 2008;152(4):471-5. 5 e1. X-3. [pmid: 18346498].
309 Scal P, Garwick A, Horvath KJ. Making Rheumtogrow: The rationale and framework for an Internet based health care transition intervention. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):451-61. X-7.
310 Scal P, Horvath K, Garwick A. Preparing for adulthood: health care transition counseling for youth with arthritis. Arthritis Rheum. Jan. 15. 2009;61(1):52-7. X-5. [pmid: 19116976].
311 Scal P, Ireland M. Addressing transition to adult health care for adolescents with special health care needs. Pediatrics. Jun. 2005;115(6):1607-12. X-5. [pmid: 15930223].
312 Schor NF. Life at the interface: Adults with “pediatric” disorders of the nervous system. Ann Neurol. 2013. Apr. 11. X-6. [pmid: 23575604].
313 Schrans DG, Abbott D, Peay HL, et al. Transition in Duchenne muscular dystrophy: An expert meeting report and description of transition needs in an emergent patient population: (Parent Project Muscular Dystrophy Transition Expert Meeting 17-18 June 2011, Amsterdam, The Netherlands). Neuromuscul Disord. Mar. 2013;23(3):283-6. X-6. [pmid: 22989602].
314 Schultz RJ. Parental experiences of transitioning their adolescent with epilepsy and cognitive impairments from pediatric to adult health care. Texas Woman's University. 2009.
315 Schultz RJ. Parental experiences transitioning their adolescent with epilepsy and cognitive impairments to adult health care. J Pediatr Health Care. Sep-Oct. 2013;27(5):359-66. X-5. [pmid: 22560804].
316 Schwartz LA, Brumley LD, Tuchman LK, et al. Stakeholder validation of a model of readiness for transition to adult care. JAMA Pediatr. Oct. 2013;167(10):939-46. X-2. [pmid: 23959392].
317 Scott LK. Developmental mastery of diabetes-related tasks in children. Nurs Clin North Am. Jun. 2013;48(2):329-42. X-3, X-6. [pmid: 23659817].
318 Serra MF, McCarthy C. Pediatric rehabilitation day treatment for children with brain injury and neurodevelopmental disorders. Med Health R I. Apr. 2010;93(4):103-5. X-4. [pmid: 20486519].
319 Shapiro JR, Germain-Lee EL. Osteogenesis imperfecta: effecting the transition from adolescent to adult medical care. J Musculoskelet Neuronal Interact. Mar. 2012;12(1):24-7. X-6. [pmid: 22373948].
320 Sharma N, Willen E, Garcia A, et al. Attitudes Toward Transitioning in Youth With Perinatally Acquired HIV and Their Family Caregivers. J Assoc Nurses AIDS Care. 2013. Jun. 25. X-5. [pmid: 23809660].
321 Sharma N, Willen E, Garcia A, et al. Attitudes toward transitioning in youth with perinatally acquired HIV and their family caregivers. J Assoc Nurses AIDS Care. Mar-Apr. 2014;25(2):168-75. X-8. [pmid: 23809660].
322 Shaw KL, Southwood TR, McDonagh JE. Growing up and moving on in rheumatology: a multicentre cohort of adolescents with juvenile idiopathic arthritis. Rheumatology (Oxford). Jun. 2005;44(6):806-12. X-5. [pmid: 15769786].
323 Shaw KL, Southwood TR, McDonagh JE. Development and preliminary validation of the ‘Mind the Gap’ scale to assess satisfaction with transitional health care among adolescents with juvenile idiopathic arthritis. Child Care Health Dev. Jul. 2007;33(4):380-8. X-5. [pmid: 17584392].
324 Shulman ST. Complex care is complicated!. Pediatr Ann. Apr. 2010;39(4):183-4. X-3. [pmid: 20411892].
325 Simmonds J, Burch M. Shared care in paediatric heart transplantation. Arch Dis Child Educ Pract Ed. Apr. 2008;93(2):37-43. X-3. [pmid: 18356304].
326 Singh SP. Transition of care from child to adult mental health services: the great divide. Curr Opin Psychiatry. Jul. 2009;22(4):386-90. X-6. [pmid: 19417667].
327 Singh SP, Paul M, Ford T, et al. Process, outcome and experience of transition from child to adult mental healthcare: multiperspective study. Br J Psychiatry. Oct. 2010;197(4):305-12. X-5. [pmid: 20884954].
328 Smith K. Asthma management in children. Nebr Nurse. Jun-Aug. 2004;37(2):26-8. quiz 8-9. X-3. [pmid: 15233013].
329 Sneed RC, May WL, Stencel C. Policy versus practice: comparison of prescribing therapy and durable medical equipment in medical and educational settings. Pediatrics. Nov. 2004;114(5):e612-25. X-3. [pmid: 15520092].
330 Sommelet D. Chronic pediatric diseases into adulthood and the challenge of adolescence. Handb Clin Neurol. 2013;111:101-5. X-6. [pmid: 23622155].
331 Spaic T, Mahon JL, Hramiak I, et al. Multicentre randomized controlled trial of structured transition on diabetes care management compared to standard diabetes care in adolescents and young adults with type 1 diabetes (Transition Trial). BMC Pediatr. 2013;13:163. X-6. [pmid: 24106787].
332 Spears AP. The Healthy People 2010 outcomes for the care of children with special health care needs: an effective national policy for meeting mental health care needs?. Matern Child Health J. May. 2010;14(3):401-11. X-3. [pmid: 18256914].
333 Speiser PW. Congenital adrenal hyperplasia: transition from chil dhood to adulthood. J Endocrinol Invest. Oct. 2001;24(9):681-91. X-3. [pmid: 11716155].
334 Spiegel HM, Futterman DC. Adolescents and HIV: prevention and clinical care. Curr HIV/AIDS Rep. May. 2009;6(2):100-7. X-6. [pmid: 19358781].
335 Steinbeck K, Brodie L. Bringing in the voices: a transition forum for young people with chronic illness or disability. Neonatal, Paediatric & Child Health Nursing. 2006;9(1):22-6. X-6.
336 Stein M. Young People's Transitions from Care to Adulthood in European and Postcommunist Eastern European and Central Asian Societies. Australian Social Work. 2014;67(1):24-38. X-7.
337 Steinkamp G, Ullrich G, Muller C, et al. Transition of adult patients with cystic fibrosis from paediatric to adult care--the patients' perspective before and after start-up of an adult clinic. Eur J Med Res. Feb. 28. 2001;6(2):85-92. X-1. [pmid: 11313196].
338 Sterling L, Nyhof-Young J, Blanchette VS, et al. Exploring internet needs and use among adolescents with haemophilia: a website development project. Haemophilia. Mar. 2012;18(2):216-21. X-3, X-4. [pmid: 21797947].
339 Stewart D, Stavness C, King G, et al. A critical appraisal of literature reviews about the transition to adulthood for youth with disabilities. Phys Occup Ther Pediatr. 2006;26(4):5-24. X-4. [pmid: 17135067].
340 Sullivan WF, Berg JM, Bradley E, et al. Primary care of adults with developmental disabilities: Canadian consensus guidelines. Can Fam Physician. May. 2011;57(5):541-53. e154. 68. X-6. [pmid: 21571716].
341 Swift KD, Hall CL, Marimuttu V, et al. Transition to adult mental health services for young people with attention deficit/hyperactivity disorder (ADHD): a qualitative analysis of their experiences. BMC Psychiatry. 2013;13:74. X-5. [pmid: 23497082].
342 Taylor A, Lizzi M, Marx A, et al. Implementing a care coordination program for children with special healthcare needs: partnering with families and providers. J Healthc Qual. Sep. 2013;35(5):70-7. X-3. [pmid: 22913270].
343 Taylor L, Tsang A, Drabble A. Transition of transplant patients with cystic fibrosis to adult care: today's challenges. Prog Transplant. Dec. 2006;16(4):329-34. quiz 35. X-6. [pmid: 17183940].
344 Thrall RS, Blumberg JH, Beck S, et al. Beyond the medical home: Special Care Family Academy for children and youth. Pediatr Nurs. Nov-Dec. 2012;38(6):331-5. X-6. [pmid: 23362633].
345 Thurgate C. Living with disability: Part 3. Communication and care. Paediatr Nurs. Jun. 2006;18(5):40-4. X-3. [pmid: 16784064].
346 Tong A, Wong G, Hodson E, et al. Adolescent views on transition in diabetes and nephrology. Eur J Pediatr. Mar. 2013;172(3):293-304. X-5. [pmid: 22576804].
347 Tracy J, Henderson D. Children and adolescents with developmental disabilities. The GP's role. Aust Fam Physician. Aug. 2004;33(8):591-7. X-3. [pmid: 15373375].
348 Tsamasiros J, Bartsocas CS. Transition of the adolescent from the children's to the adults' diabetes clinic. J Pediatr Endocrinol Metab. Apr. 2002;15(4):363-7. X-6. [pmid: 12008681].
349 Tuchman L, Schwartz M. Health outcomes associated with transition from pediatric to adult cystic fibrosis care. Pediatrics. Nov. 2013;132(5):847-53. X-3, X-5. [pmid: 24144711].
350 Tuchman LK, Slap GB, Britto MT. Transition to adult care: experiences and expectations of adolescents with a chronic illness. Child Care Health Dev. Sep. 2008;34(5):557-63. X-5. [pmid: 18796047].
351 Valcarcel T. Role of the primary care provider in transitioning patients with juvenile arthritis. Pediatr Ann. Nov. 2012;41(11):469-70. X-6. [pmid: 23814935].
352 Valenzuela JM, Buchanan CL, Radcliffe J, et al. Transition to adult services among behaviorally infected adolescents with HIV--a qualitative study. J Pediatr Psychol. Mar. 2011;36(2):134-40. X-5. [pmid: 19542198].
353 van den Heuvel ME, van der Lee JH, Cornelissen EA, et al. Transition to the adult nephrologist does not induce acute renal transplant rejection. Nephrol Dial Transplant. May. 2010;25(5):1662-7. X-5. [pmid: 20026560].
354 van der Toorn M, Cobussen-Boekhorst H, Kwak K, et al. Needs of children with a chronic bladder in preparation for transfer to adult care. J Pediatr Urol. Aug. 2013;9(4):509-15. X-5. [pmid: 22695375].
355 van Pelt PA, Kruize AA, Goren SS, et al. Transition of rheumatologic care, from teenager to adult: which health assessment questionnaire can be best used?. Clin Exp Rheumatol. Mar-Apr. 2010;28(2):281-6. X-3. [pmid: 20483054].
356 Van Riper CL, Wallace LS. Position of the American Dietetic Association: Providing nutrition services for people with developmental disabilities and special health care needs. J Am Diet Assoc. Feb. 2010;110(2):296-307. X-6. [pmid: 20112461].
357 van Staa A, van der Stege HA, Jedeloo S, et al. Readiness to transfer to adult care of adolescents with chronic conditions: exploration of associated factors. J Adolesc Health. Mar. 2011;48(3):295-302. X-5. [pmid: 21338902].
358 Van Walleghem N. Editorial commentary. Bridging the gap: transition from pediatric to adult diabetes care. Canadian Journal of Diabetes. 2005;29(1):10-1. X-6.
359 Vinchon M, Dhellemmes P. The transition from child to adult in neurosurgery. Adv Tech Stand Neurosurg. 2007;32:3-24. X-5. [pmid: 17907472].
360 Visentin K, Koch T, Kralik D. Adolescents with Type 1 Diabetes: transition between diabetes services. J Clin Nurs. Jun. 2006;15(6):761-9. X-5. [pmid: 16684172].
361 Volta C, Luppino T, Street ME, et al. Transition from pediatric to adult care of children with chronic endocrine diseases: a survey on the current modalities in Italy. J Endocrinol Invest. Feb. 2003;26(2):157-62. X-5. [pmid: 12739744].
362 Waite A. Helping Adolescents With CP Transition Into Adulthood. OT Practice. 2014;19(3):5. X-6.
363 Waite E, Laraque D. Pediatric organ transplant patients and long-term care: a review. Mt Sinai J Med. Dec. 2006;73(8):1148-55. X-6. [pmid: 17285215].
364 Wan J. Adolescent urology update. Adolesc Med State Art Rev. Apr. 2013;24(1):273-94. X-2, X-3, X-4, X-6. [pmid: 23705530].
365 Warren-Boulton E, Gallivan JM. Pediatric to Adult Care Transition Challenges and NDEP Resources… National Diabetes Education Program. School Nurse News. 2011;28(3):29-31. X-3.
366 Watson AR, Shooter M. Transitioning adolescents from pediatric to adult dialysis units. Adv Perit Dial. 1996;12:176-8. X-6. [pmid: 8865896].
367 Watson L. Too old at 18: a parent's view of transition. Paediatr Nurs. Sep. 2006;18(7):25. X-6. [pmid: 16986752].
368 Webb AK, Jones AW, Dodd ME. Transition from paediatric to adult care: problems that arise in the adult cystic fibrosis clinic. J R Soc Med. Suppl 40. 2001;94:8-11. X-6. [pmid: 11601165].
369 Wells CK, McMorris BJ, Horvath KJ, et al. Youth report of healthcare transition counseling and autonomy support from their rheumatologist. Pediatr Rheumatol Online J. 2012;10(1):36. X-5. [pmid: 23151125].
370 While AE, Mullen J. Living with sickle cell disease: the perspective of young people. Br J Nurs. Mar 25-Apr 7. 2004;13(6):320-5. X-4. [pmid: 15126965].
371 White PH. Transition: a future promise for children and adolescents with special health care needs and disabilities. Rheum Dis Clin North Am. Aug. 2002;28(3):687-703. viii. X-6. [pmid: 12380376].
372 Wiener LS, Zobel M, Battles H, et al. Transition from a pediatric HIV intramural clinical research program to adolescent and adult community-based care services: assessing transition readiness. Soc Work Health Care. 2007;46(1):1-19. X-1, X-3. [pmid: 18032153].
373 Wilens TE, Rosenbaum JF. Transitional aged youth: a new frontier in child and adolescent psychiatry. J Am Acad Child Adolesc Psychiatry. Sep. 2013;52(9):887-90. X-6. [pmid: 23972688].
374 Williams WG. Advanced practice nurses in a medical home. J Spec Pediatr Nurs. Jul. 2006;11(3):203-6. X-3. [pmid: 16774532].
375 Wills KE, Nelson SC, Hennessy J, et al. Transition planning for youth with sickle cell disease: embedding neuropsychological assessment into comprehensive care. Pediatrics. Dec. Suppl 3. 2010;126:S151-9. X-3. [pmid: 21123479].
376 Witchel SF, Recabarren SE, Gonzalez F, et al. Emerging concepts about prenatal genesis, aberrant metabolism and treatment paradigms in polycystic ovary syndrome. Endocrine. Dec. 2012;42(3):526-34. X-3. [pmid: 22661293].
377 Withers AL. Management issues for adolescents with cystic fibrosis. Pulm Med. 2012;2012:134132. X-6. [pmid: 22991662].
378 Wolfstadt J, Kaufman A, Levitin J, et al. The use and usefulness of My Health Passport: An online tool for the creation of a portable health summary. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):499-506. X-5.
379 Wong LH, Chan FW, Wong FY, et al. Transition care for adolescents and families with chronic illnesses. J Adolesc Health. Dec. 2010;47(6):540-6. X-5. [pmid: 21094430].
380 Wood D, Reiss JG, Ferris ME, et al. Transition from pediatric to adult care. International Journal of Child and Adolescent Health. 2012-09-10. 2010;3(4):445-7. X-3.
381 Wood E. The child with cerebral palsy: diagnosis and beyond. Semin Pediatr Neurol. Dec. 2006;13(4):286-96. X-6. [pmid: 17178359].
382 Wren C, O'sullivan JJ. Survival with congenital heart disease and need for follow up in adult life. Heart. Apr. 2001;85(4):438-43. X-5. [pmid: 11250973].
383 Wynn K, Stewart D, Law M, et al. Creating connections: a community capacity-building project with parents and youth with disabilities in transition to adulthood. Phys Occup Ther Pediatr. 2006;26(4):89-103. X-4. [pmid: 17135071].
384 Young G. From boy to man: recommendations for the transition process in haemophilia. Haemophilia. Jul. Suppl 5. 2012;18:27-32. X-3. [pmid: 22757681].
385 Zabel TA, Linroth R, Fairman AD. The Life Course Model Web site: an online transition-focused resource for the spina bifida community. Pediatr Clin North Am. Aug. 2010;57(4):911-7. X-3, X-4. [pmid: 20883881].
386 Zebracki K, Anderson CJ, Chlan KM, et al. Outcomes of adults with pediatric-onset spinal cord injury: longitudinal findings and implications on transition to adulthood. Topics in Spinal Cord Injury Rehabilitation. 2010;16(1):17-25. X-6.