# Summary of Gray Literature

Table C-1 Transition resources identified from Internet searches

Resource Name | Description | Organization/Institution | Condition | Consensus / Guideline | Portal | Patient Material | Clinician Guide | Fact Sheet / Data | Assessment / Evaluation Tool
Autism Transition Handbook: Health Care | Information on transition resources for individuals with autism spectrum disorder and links to state-level information. | Devereux Foundation | Autism | | ● | ●
Good2Go Transition Program | Program to prepare youth with chronic health conditions to leave the hospital by the age of 8 and use adult health care services successfully. | The Hospital for Sick Children | Chronic health condition | | ● | ● | | | ●
The Adolescent Leadership Council (TALC) | Mentor program for chronically ill adolescents to prepare for transition to adulthood. | Hasbro Children's Hospital | Chronic health condition | | ● | ●
Taking Responsibility for Adolescent/Adult Care (ON TRAC) | Model of transition care for adolescents with chronic health conditions. | Children's and Women's Health Centre | Congenital heart disease | | | ● | ● | | ●
Cystic Fibrosis Transition Program | Structured transition program. | University of Michigan | Cystic fibrosis | | | ●
Cystic Fibrosis Transition Program | Specialized service partners with patients family to facilitate transition to adult care. | Lurie Children's Memorial Hospital | Cystic fibrosis | | | ●
CART Model Programs | White paper discusses model programs for transition from childhood and adolescence to adult. | The Special Hope Foundation | Developmental disability | | | ● | ●
Elizabeth M. Boggs Center on Developmental Disabilities | Developing a New Jersey Developmental Disabilities Transition to Adult Health Care Forum. | Rutgers Robert Wood Johnson Medical School | Developmental disability | | ●
Florida Developmental Disabilities Council: Health Care Transition | Health care transition training modules, workbook, and other resources for young people with developmental disabilities. | Florida Developmental Disabilities Council | Developmental disability | | ●
Moving from Pediatric to Adult Health Care, Healthy Transitions NY | Website developed for youth with developmental disabilities, family caregivers, service coordinators, and health care providers. | Golisano Children's Hospital, State University of New York Upstate Medical University | Developmental disability | | ● | ● | | ●
Special Hope Foundation | Foundation funds projects on delivery of health care to adults with developmental disabilities. | The Special Hope Foundation | Developmental disability | | ●
Taking Charge of My Health: Partners in Transition | Special Hope Foundation funded project to develop and test training modules for parents of young adults with developmental disabilities through transition from pediatric to adult care. | Westchester Institute for Human Development | Developmental disability | | | ●
Tools for primary care providers | Provides a list of forms and tools to assist providers of adults with developmental disabilities. | Surrey Place Centre | Developmental disability | | | | ●
The Maestro Project | A community resource and transition support service for young adults with type I and type II diabetes. | Department of Pediatrics and Child Health | Diabetes | | ● | ● | ●
disability.gov | Federal government website catalogue of nationwide disability programs and services. | U.S. Department of Labor | Disability | | ●
The Best Journey to Adult Life | Youth, family, and service providers identified best practices for transition to adulthood for youth with disabilities. | CanChild Centre for Childhood Disability Research, McMaster University | Disability | ● | | ● | ●
Transition Planning for Adolescents with Special Health Care Needs: Information for Families and Teens | Booklet for youth transitioning to adulthood with a section on health care issues. | Institute for Community Inclusion, University of Massachusetts | Disability | | ● | ● | | ● | ●
Transitioning Youth: Healthcare | Resources and tools to prepare youth with disabilities for health care transition. | Governor's Interagency Transition Council | Disability | | ● | ●
Work Ability Utah: Transition to Adult Health Care | Resources for assessment and planning of health care transitions for youth with special health care needs. | Utah Department of Health | Disability | | ● | ● | | | ●
Consensus statement on the management of GH-treated adolescent in the transition to adult care | Consensus workshop summary of transition for growth hormone treated patients in transition from pediatric to adult care. | European Society for Paediatric Endocrinology | Endocrine disease | ● | | | ●
Young Person Clinic | Special clinic with pediatric and adult endocrine teams | Royal Manchester Children's Hospital | Endocrine disease | | | ●
Adolescent Epilepsy Transition Clinic | Nurse led transition clinic within an epilepsy program. | University of Alberta Hospital | Epilepsy | | | ● | ● | | ●
900 Clinic Transition Service | Specialty multidisciplinary clinic patients attend for 6-8 years. | Imperial College Healthcare NHS Trust | HIV | | | ●
Transition from CAMHS to adult mental health services (TRACK): a study of service organisation, policies, process and user and carer perspective | National Institutes for Health Research funded transition project on organizational and clinical determinants of effective transition from child and adolescent mental health services to adult psychiatric services. | University of Warwick | Mental health | | | | | | ●
National Center for Medical Home Implementation: Transitions | Links to resources on appropriate care transitions, guidance documents, and opinion statements. | American Academy of Pediatrics | Not specified | | ●
Transition to Adult Health Services | Information for providers and patients transitioning to adult health care. | Great Ormond Street Hospital for Children | Not specified | | | ● | ● | ● | ●
Improving Sickle Cell Transitions of Care through Health Information Technology | Ongoing project to understand the needs of Sickle cell disease patients, caregivers, and providers and create a toolkit for Sickle cell disease care transitions. | National Initiative for Children's Healthcare Quality (NICHQ) | Sickle cell disease | | ●
Recommended Curriculum for Transition from Pediatric to Adult Medical Care for Adolescents with Sickle Cell Disease | Suggested topics, methods, and efficacy measurements and proposes steps for transitioning by age group with subsections on medical issues. | National Initiative for Children's Healthcare Quality (NICHQ) | Sickle cell disease | ● | | | ●
Sickle Cell Disease Transition Program | Educational program coordinated by Child Life Specialist with didactic information, web-based and print resources. | Department of Pediatrics, Duke University | Sickle cell disease | | | ● | | | ●
Sickle Cell Disease Treatment Demonstration Program | Ongoing project of quality improvement strategies for care of individuals with sickle cell disease. | National Initiative for Children's Healthcare Quality (NICHQ) | Sickle cell disease | | ●
Adolescent Health Transition Project | Information, links, and material on transition from pediatric to adult health care for adolescents with special health care needs. | Center on Human Development and Disability, University of Washington | Special health need | | ● | ● | ● | ● | ●
Adolescent Transition for People with Special Health Care Needs | Links to brochures summarizing transition, checklists for youth, and other resources. | Rhode Island Department of Health | Special health need | | | ● | ● | ● | ●
Catalyst Center: Youth Transition, Telemedicine and Other Capacity Building Services | Funded by Maternal and Child Health Bureau to support youth transition, telemedicine, and other capacity building services. | Catalyst Center, Boston University School of Public Health | Special health need | | ●
Commission for Children with Special Health Care Needs: Transition Resources | Links to sites with information for helping young people with independence in health care | Kentucky Cabinet for Health and Family Services | Special health need | | ●
Creating Healthy Futures (CHF clinic) | Transition clinic for adolescents and young adults with special health needs. | Department of Nursing, University of Southern California | Special health need | | | | ●
Got Transition? Center for Health Care Transition Improvement | Guidance and tools to aid in health care transitions for adolescents and young adults. | The National Alliance to Advance Adolescent Health | Special health need | ● | ● | ● | ● | ● | ●
Health Transition Wisconsin | Web site with transition tools and links to additional resources for families and clinicians | Health Transition Wisconsin | Special health need | | ● | ● | ●
Healthy and Ready to Work, National Resource Center | Includes resources for understanding systems, access to quality health care, and increasing involvement of youth. | Maternal and Child Health Bureau | Special health need | | ● | ●
Kentucky Youth Transitioning to Employment and Comprehensive Healthcare (KY TEACH) | Assist young people with special health care needs to find medical homes and employment with health insurance. | Kentucky Cabinet for Health and Family Services | Special health need | | ● | ● | | | ●
Navigating Health Care Transitions | Information about pilot project and tool for recommendations by age group and life domain. | Family Voices Colorado | Special health need | | | ●
Office for Genetics & Children with Special Health Care Needs: Health Care Transition | Resource site for youth and providers, including an adult care notebook. | Maryland Department of Health and Mental Hygiene | Special health need | | ● | ● | ●
Roadmap for Transitioning Adolescents from a Pediatric to an Adult Practice | Document developed by providers and parents to address transition from pediatric to adult care for patients with special health needs. | Children's Hospitals and Clinics of Minnesota | Special health need | | | ● | ●
Special Medical Services: Health Care Transition | Description of planning process by the Specialized Medical Services and Health Care Transition Coalition to promote quality of care during the health care transition. | New Hampshire Department of Health and Human Services | Special health need | ● | | ● | ● | ●
Tools for Transition | Educational resources for youth, a transition resource directory, and health care transition checklist. | Massachusetts Family Voices | Special health need | | ●
Transition Age Youth | Transition planning for adolescents with special health care needs and disabilities. | Massachusetts Child Psychiatry Access Project | Special health need | | | ● | ●
Transition Information and Resources for Families and Youth | Transition resources for youth with special health care needs. | Louisiana Department of Health and Hospitals | Special health need | | ●
Transition Program | Provides support for medically complex patients ready to transition from pediatric to adult care. | Lurie Children's Memorial Hospital | Special health need | | ● | ● | ● | ●
Transition to Adult Health Care: A Training Guide in Two Parts | Workshop guide and materials for parents, and youth with special health care needs ready to transition to adult healthcare. | Waisman Center, University of Wisconsin Madison | Special health need | | | ● | | ●
Spina Bifida Transition Program | Describes processes, strategies, and tools to establish a transition program. | Children's Hospital of Wisconsin | Spina bifida | | | | ●
| | | | 5 | 26 | 32 | 21 | 8 | 12

Data Coding and Definitions for Table C-1

Resource Characteristics
Resource Name: Name of resource Description: Brief description Organization / Institution: Name of organization, hospital, etc. and geographic location Condition: Disease or condition of the target population; - cystic fibrosis; - congenital heart disease; - cerebral palsy; - diabetes; - any endocrine disease except diabetes (e.g. adrenal hyperplasia); - HIV; - mental health; - any rheumatology disease (e.g., juvenile idiopathic arthritis); - sickle cell disease; - special health need, may be generic or various; - transplant; - physical disability, may be generic or various; - developmental disability, may be generic or various; - chronic health condition except for those specified above, may be generic or various; - other; - not specified
Resource Components; coded as 0=no; 1=yes; X=unclear
Consensus / Guideline: Clear statements issued by organization or professional group usually identified as guideline, practice parameter, consensus statement, etc. Portal: Links to various resources or materials Patient Material: The resource or information targets the patient or the patient family Clinician Guide: The resource of information targets the provider/ clinician Facts / Data Sheet: May be specific or generic information on transition- may include statistics, facts, summary points- but is generally succinct. Assessment / Evaluation Tool: Assessment or evaluation of transition readiness, transition process, or transition methods

Table C-2 U.S. Federal and State-level transition resources and programs

Title | Location | Description | Organization | URL
Achieving the Outcomes for CSHCN | HI | Transition to Adult Health Care, Work, & Independence is a major outcome of focus; section links to original guides and workbooks | State of Hawaii, Department of Health, Children with Special Health Needs Branch | http://health.hawaii.gov/cshcn/cshcnoutcomes/
Adolescent Services, Helping You Transition to Adulthood: Resources for New Jersey's Youth | NJ | Contains resource guides and outside resources for transitioning adolescents | New Jersey Department of Children and Families | http://www.nj.gov/dcf/adolescent/
Adolescent Transition for People with Special Health Care Needs | RI | Links to brochures summarizing transition, checklists for youth, Youth transition workbook (with section on healthcare advocacy), and other resources | State of Rhode Island Department of Health | http://www.health.ri.gov/specialhealthcareneeds/about/adolescenttransition/
Carolina Health and Transition (CHAT): A Guide to Transition from Pediatric to Adult Health Care | NC | Handbook for transitioning from pediatric to adult care | North Carolina Division of Public Health: Women's and Children's Health: Children and Youth | http://www.ncdhhs.gov/dph/wch/doc/lhd/CHAT/Youth_Guide_12-09.pdf
Commission for Children with Special Health Care Needs: Transition Resources | KY | Assist young people with special healthcare needs to find medical homes and employment with health insurance; create system changes that promote smooth transitions from school to work and from pediatric to adult healthcare; links to sites with information for helping young people with independence in health care. | Commission for Children with Special Health Care Needs, Kentucky Cabinet for Health and Family Services | http://chfs.ky.gov/ccshcn/ccshcntransition.htm
Continuum of Care | SC | Handbooks and manuals for transitioning to adulthood, with sections on health | Governor's Office of Executive Policy and Programs | http://www.oepp.sc.gov/coc/default.html
CSH Healthcare Transitioning | WY | Suggestions and resources for transitioning to adult health services | Wyoming Department of Health | http://www.health.wyo.gov/familyhealth/csh/transitions.html
DMH Transitional Age Youth Initiative | MA | Links to Young Adult Resource Guide with a section on health | Massachusetts Department of Mental Health | http://www.mass.gov/eohhs/gov/departments/dmh/transitional-age-youth-initiative.html
Health Care Program for Children with Special Needs (HCP) | CO | Page has a section that links to transition to adult health care resources - some created by state, some external | Colorado Department of Public Health and Environment | http://www.colorado.gov/cs/Satellite/CDPHE-PSD/CBON/1251617590646
Health Transition Wisconsin | WI | Web site with transition tools including videos, a checklist, and pocket guide, and links to additional resources for families and clinicians | Wisconsin Regional Centers, Children and Youth with Special Health Care Needs | http://www.healthtransitionwi.org/
Healthy and Ready to Work, National Resource Center | US | Website for a project that has ended, but includes resources for understanding systems, access to quality health care, and increasing involvement of youth. | Maternal and Child Health Bureau | http://www.syntiro.org/hrtw/
Independent Living Program | NV | Program with resources to prepare foster youth to transition to adulthood; medical care is one topic | Nevada Division of Child and Family Services | http://www.dcfs.state.nv.us/dcfs_independentliving.htm
Now that you're in high school… it's time to be more in charge of your health | FL | Booklet directs teens with SHN to be more in charge of their health care, focusing on both teens and the transition to adulthood | Florida Department of Health and University of FL | http://www.floridahealth.gov/alternatesites/cms-kids/kids_teens/documents/highschool_booklet.pdf
Office for Genetics & Children with Special Health Care Needs: Health Care Transition | MD | Office For Genetics And People With Special Health Care Needs resource site for youth and providers, including an adult care notebook | Maryland Department of Health and Mental Hygiene | http://phpa.dhmh.maryland.gov/genetics/SitePages/Health_Care_Transition.aspx
Oklahoma Healthy Transitions Initiative | OK | Initiative to establish consortium of statewide community-based services for transitioning youth; also has resource guides | Oklahoma Department of Mental Health and Substance Abuse Services | http://ok.gov/odmhsas/Mental_Health_/Children,_Youth,_and_Family_Services/Systems_of_Care/Oklahoma_Healthy_Transitions_Initiative_%28OHTI%29/
Special Education and Support Services: Secondary Transition | IL | Links to healthcare related webinar | Illinois State Board of Education | http://www.isbe.state.il.us/spec-ed/html/total.htm
Special Medical Services: Health Care Transition | NH | Description of planning process by the Specialized Medical Services and Health Care Transition Coalition to promote quality of care during the health care transition from adolescent to adult, including transition checklist and timeline for providers and other tools | New Hampshire Department of Health and Human Services | http://www.dhhs.state.nh.us/dcbcs/bds/sms/transition.htm
Systems in Sync: Transition to Adulthood | KS | Project focusing on guiding young adults with SHN through the transition to adulthood, specifically integrating health transition with work, education, and independent living. | Kansas Department of Health and Environment | http://www.systemsinsync.org/goals_transition.htm
Transition for Young Adults | DE | Page contains facts, principles, and local resources for transitioning | Healthy Delawareans with Disabilities | http://www.gohdwd.org/health-care/transition-for-young-adults/
Transition Guides | ID | Interactive guides to health care transition separated by age groups | Idaho Department of Health and Welfare | http://www.healthandwelfare.idaho.gov/Children/ChildrensSpecialHealthProgram/HealthCareTransitiontoAdulthood/tabid/1472/Default.aspx
Transition Health Care Checklist: Transition to Adult Living in Pennsylvania | PA | Checklist, resources, steps to assist youth and families in transitioning to adult health and health care | Pennsylvania Department of Health | http://www.portal.state.pa.us/portal/server.pt/community/special_kids_network/14205/transition_health_care_checklist/558090
Transition Information | TX | Information and links to resources for patients, patient families, and providers on transition of youth with special health needs from pediatric to adult care. | Texas Department of State Health Services | http://www.dshs.state.tx.us/cshcn/transinfo.shtm
Transition Information and Resources for Families and Youth | LA | Transition resources for youth with special health care needs, including a guide to family involvement and resources by state region | Louisiana Department of Health and Hospitals | http://dhh.louisiana.gov/index.cfm/page/1137
Transition Information Packet | IA | Booklet on transition for youth exiting the foster care system, with a section on health | Iowa Department of Human Services | http://www.dhs.iowa.gov/Consumers/Child_Welfare/Transition_Services/Transitioning%20to%20Adulthood.html
Transition Issues | OH | Links to a document on medical transition | Ohio Department of Health | http://www.odh.ohio.gov/odhprograms/cmh/cwmh/infofam/cmhfmtrn.aspx
Transition Resources | MT | Page of outside health care transition resources | Montana Department of Public Health and Human Services | http://www.dphhs.mt.gov/publichealth/cshs/transitionresources.shtml
Transition to Adulthood | MI | Page contains original guides and resource manuals for health care transition | Michigan Department of Community Health | http://www.michigan.gov/mdch/0,4612,7-132-2942_4911_35698-135030--,00.html
Transition to Adulthood | ND | Page has a section that links to external pediatric to adult health resources | North Dakota Department of Health, Children's Special Health Services | http://www.ndhealth.gov/cshs/TransitionToAdulthood.htm
Transitioning Youth: Healthcare | MD | Resources and tools to prepare youth with disabilities for health care transition | State of Maryland (collaboration of many departments) | http://www.mdtransition.org/Health%20Care.htm
Work Ability Utah: Transition to Adult Health Care | UT | Resources for assessing current status and planning health care transitions for youth with special health care needs | Utah Department of Health | http://www.workabilityutah.org/community/healthy/transitionhealthcare.php
Young Adults in Transition | OR | Links to a few resources for young adults in transition | Oregon Department of Human Services, Addiction and Mental Health Services | http://www.oregon.gov/oha/amh/pages/child-mh-soc-in-plan-grp/main.aspx#young
Young Adults Transition Plan: Your Future / Your Life | WA | Designed to guide youth towards adult life and additional responsibility in healthcare | Washington State Department of Health | http://here.doh.wa.gov/materials/transition-plan-young-adults/13_CSHCN-18yr_E11L.pdf
Youth and Transition Services | MN | Resources for transitioning youth with mental health needs | Minnesota Department of Human Services | http://www.dhs.state.mn.us/main/idcplg?IdcService=GET_DYNAMIC_CONVERSION&RevisionSelectionMethod=LatestReleased&dDocName=dhs16_167209
Youth in Transition Grant | VT | Project to support youth transitioning to adulthood through community supports, events, resources - access to a medical home is one of the desired outcomes | Vermont Department of mental Health | http://www.youth-in-transition-grant.com/
Youth in Transition to Adulthood | TN | Links to a few resources and programs for transitioning youth, some for health and mental health | Tennessee Division of Mental Health Services | http://tn.gov/mental/children/child_youth_adult.shtml
Youth Transitions, Office for Children with Special Health Care Needs | AZ | Page on government website that links to health transition resources | Arizona Department of Health Services | http://www.azdhs.gov/phs/owch/ocshcn/youth-transition.htm
Youth with Special Health Care Needs | CT | Page contains some original resources on transitioning to adult health care (for young adults, parents, and providers) and links to some external resources | Connecticut Department of Public Health | http://www.ct.gov/dph/cwp/view.asp?a=3138&q=432684

Table C-3 Consensus statements for transition care

Reference Organization(s) Country | Brief description
American Academy of Pediatrics, the American Academy of Family Physicians, and the American College of Physicians-American Society of Internal Medicine, 2002^1^ A consensus statement on health care transitions for young adults with special health care needs United States | Critical first steps that the medical profession needs to take to realize the vision of a family-centered, continuous, comprehensive, coordinated, compassionate, and culturally competent health care system.
Bell et al., Adolescent transition to adult care in sold organ transplantation: a consensus conference report. (2008){#728} American Society of Transplantation, Pediatric Committee United States | Recommendations from a consensus conference for transition of children who have received solid organ transplants.
Clayton et al., Consensus statement on the management of the GH-treated adolescent in the transition to adult care. (2005){#1393} European Society of Paediatric Endocrinology, Consensus Development Conference England | Summary of discussions at a consensus workshop related to issues in caring for GH-treated patients in the transition from pediatric to adult life.
Nutt et al., Evidence-based guidelines for management of attention-deficit/hyperactivity disorder in adolescents in transition to adult services and in adults. (2007){#954} British Association for Psychopharmacology, Consensus Development Conference England | Consensus conference to review the body of evidence on childhood ADHD and the growing literature on ADHD in older age groups. Much of this initial guidance on managing ADHD in adolescents in transition and in adults is based on expert opinion derived from childhood evidence.
Peters and Laffel. Diabetes care for emerging adults: recommendations for transition from pediatric to adult diabetes care systems. (2011){#226} American Diabetes Association Transitions Working Group, Consensus Development Conference United States | Consensus statement provides a framework for health care delivery during the transition period and an agenda for future research for youth and young adults with diabetes and their health care providers.
Rosen et al., Transition to adult health care for adolescents and young adults with chronic conditions. (2003){#1194} Society for Adolescent Medicine United States | Endorsement of national consensus statement on Health Care Transitions for young adults with special health needs and additional recommendations from the Society for Adolescent Medicine.
Sable et al., Best practices in managing transition to adulthood for adolescents with congenital heart disease: the transition process and medical and psychosocial issues. (2011){#2204} American Heart Association United States | Recommendation for transition care for adolescents with congenital heart disease. Address timing, social and family dynamics, health supervision issues, and sexuality, pregnancy and reproductive issues.
Sullivan et al., Primary care of adults with developmental disabilities. (2011){#2205} Canadian Consensus Guidelines, Colloquium on Guidelines for the Primary Health Care of Adults with Developmental Disabilities (March 20, 2009) Canada | Colloquium on guidelines for the primary health care of adults with developmental disabilities held in March of 2009 updates the 2006 Canadian guidelines for primary care of adults with developmental disabilities.
Van Riper et al., Position of the American Dietetic Association: providing nutrition services for people with developmental disabilities and special health care needs. (2010){#1625} American Dietetic Association United States | Consensus statement developed by the panel of adult and pediatric nephrologists.
Watson et al., Transition from pediatric to adult renal services. (2011){#1381} International Society of Nephrology; International Pediatric Nephrology Association, Consensus Development Conference United States | Consensus statement developed by the panel of adult and pediatric nephrologists.
Webb et al., Building consensus on transition of transplant patients from paediatric to adult healthcare. (2010){#480} Consensus Development Conference England | Seven consensus statements representative of the current opinion of families and the UK transplant community.

Table C-4 Description of selected transition programs

Citation Location | Model | Population | Setting | Description
Jurasek et al., 2010^7^ Edmonton, Canada ** | Adolescent Epilepsy Transition Clinic | Epilepsy | University of Alberta Hospital | Nurse-led transition clinic within comprehensive epilepsy program
Kripke et al., 2011^8^ California, U.S. | CART model program | Developmental disability | Administered by public health insurance plan | Includes medical home, center of excellence, and health advocacy services
Betz and Redcay, 2003^9^ California, U.S. | Creating Healthy Futures | Special health care needs | Department of Nursing Clinic, University of Southern California | Family nurse practitioner, interagency team of child and adult providers
Amaria et al., 2011^10^ Toronto, ON, Canada | Good2Go Transition Program | Chronic health conditions | The Hospital for Sick Children | Preparation for youth with chronic health conditions to leave the hospital and use adult healthcare services successfully
Paone, et al., 2006^11^ British Columbia | ON TRAC | Pediatric transplant | Children's and Women's Health Care Centre | Developmentally appropriate (based upon adolescent development) teaching including tasks and skills and a care pathway to outline management practice and quality transitional care.
Kaufmann Rauen et al., 2013^12^ Wisconsin, U.S. | Spina Bifida Transition Program | Spina bifida | Children's hospital | Partnership between pediatric and adult providers, guided by the Transition Care Model and the Ecological Model of Secondary Conditions and Adaptation
Stewart, et al. 2009^13^ Hamilton, ON, Canada | The Best Journey to Adult Life | Developmental disability | CanChild Centre for Childhood Disability Research, McMaster University | Best practices for the transition to adulthood for youth with disabilities
Smith et al., 2011^14^ North Carolina, U.S. | Sickle Cell Disease Transition | Sickle cell disease | Duke Department of Pediatrics | Coordinated by a child life specialist
Vanelli et al., 2004^15^ ** | Parma protocol | Adolescents with type 1 diabetes | Pediatric, adult specialty clinic Pediatric and adult providers | Protocol for an uninterrupted procedure for transfer including introduction to the adult provider prior to transition and attendance by the pediatrician at the first adult visit. Transition occurred when the patient and parents agreed
Chaudhry et al., 2013^16^ Michigan, U.S. ** | Structured transition program | Adults with cystic fibrosis | Academic medical center | Structured transition program beginning early in adolescence, focusing on developing independence. Included a transition coordinator and participation of the adult pulmonologist in the pediatric clinic until readiness is achieved.
Gerber et al., 2007^17^ Illinois, US | STYLE | Young adults with diabetes | Inner-city clinics and childhood diabetes registry Diabetes educator | Internet-based transition program including information on DM, goal-setting exercises with feedback, role-playing, empowerment and communication skills
Maslow et al., 2012^18^ Rhode Island, U.S. ** | The Adolescent Leadership Council (TALC) | Individuals with a chronic illness aged 13-19 years | Hasbro Children's hospital Pediatric and psychiatry residents, child life therapists, medical students, supervised by pediatric and psychiatry attending physicians | 10-month group mentoring program based on the Positive Youth Development framework
Van Walleghem et al., 2006^19^ and 2008^20^ Manitoba, Canada ** | The Maestro Project | Youth with type 1 diabetes aged under 18 years | Community clinics, diabetes education resource center | Systems navigator model, administrative coordinator maintains phone and email contact with patients to identify barriers. Delivery methods include a comprehensive website, a bimonthly newsletter, a drop-in group and educational events
Hankins et al., 2012^21^ Tennessee, U.S. ** | Transition Pilot Program | Youth with sickle cell disease aged 17-19 years | Pediatric hospital Pediatric hematology staff | Transition Pilot Program including a tour of adult SCD programs, lunch discussion with pediatric staff and scheduling of the first adult visit by the pediatric hematology case manager
Chaturvedi et al., 2009^22^ Australia ** | Transition program | Pediatric kidney transplant recipients | Children's hospital renal clinic Transition coordinator, transition adult nephrologist, and transition nurse | Transition clinic, development of self-management skills and a written transition summary
Craig et al., 2007^23^ Australia | Transition program | Youth with cystic fibrosis | Children's hospital | Phase-based transition program, including a preparation phase in early adolescence and an active phase that begins around age 16.
Byron and Madge, 2001^24^ | Transition Programme | Youth with cystic fibrosis | Children's hospital
Price et al., 2011^25^ UK | Transitions Pathway model | Youth with type 1 diabetes aged 16-18 years | Hospital | Transitions Pathway model including 4 preparatory visits leading up to transfer to the 16 – 25 year old clinic focusing on fitting diabetes care into current and future life and ensuring that patients received adequate advice. Upon request, pediatrician attended first visit in the young adult clinic.
Gleeson et al., 2013^26^ UK ** | Young Person Clinic | Individuals with congenital adrenal hyperplasia | Children's hospital Pediatric and adult endocrine teams | Young Person Clinic (YPC) at which the youth is introduced to an adult endocrinologist
Bent et al., 2002^27^ UK ** | Young Adult Teams | Youth with long-term physical disability | 4 regions | Young Adult Teams, including multidisciplinary teams including a consultant in rehabilitation medicine, a psychologist, therapists and a social worker

** also in the transition program evaluation table in GQ3

## References for Appendix C

1 A consensus statement on health care transitions for young adults with special health care needs. Pediatrics. Dec. 2002;110(6 Pt 2):1304-6. [pmid: 12456949].
2 Clayton PE, Cuneo RC, Juul A, et al. Consensus statement on the management of the GH-treated adolescent in the transition to adult care. Eur J Endocrinol. Feb. 2005;152(2):165-70. [pmid: 15745921].
3 Nutt DJ, Fone K, Asherson P, et al. Evidence-based guidelines for management of attention-deficit/hyperactivity disorder in adolescents in transition to adult services and in adults: recommendations from the British Association for Psychopharmacology. J Psychopharmacol. Jan. 2007;21(1):10-41. [pmid: 17092962].
4 Peters A, Laffel L. Diabetes care for emerging adults: recommendations for transition from pediatric to adult diabetes care systems: a position statement of the American Diabetes Association, with representation by the American College of Osteopathic Family Physicians, the American Academy of Pediatrics, the American Association of Clinical Endocrinologists, the American Osteopathic Association, the Centers for Disease Control and Prevention, Children with Diabetes, The Endocrine Society, the International Society for Pediatric and Adolescent Diabetes, Juvenile Diabetes Research Foundation International, the National Diabetes Education Program, and the Pediatric Endocrine Society (formerly Lawson Wilkins Pediatric Endocrine Society). Diabetes Care. Nov. 2011;34(11):2477-85. [pmid: 22025785].
5 Watson AR, Harden PN, Ferris ME, et al. Transition from pediatric to adult renal services: a consensus statement by the International Society of Nephrology (ISN) and the International Pediatric Nephrology Association (IPNA). Kidney Int. Oct. 2011;80(7):704-7. [pmid: 21832978].
6 Webb N, Harden P, Lewis C, et al. Building consensus on transition of transplant patients from paediatric to adult healthcare. Arch Dis Child. Aug. 2010;95(8):606-11. [pmid: 20515964].
7 Jurasek L, Ray L, Quigley D. Development and implementation of an adolescent epilepsy transition clinic. J Neurosci Nurs. Aug. 2010;42(4):181-9. [pmid: 20804112].
8 Transition from paediatric to adult endocrine care in patients with childhood onset growth hormone deficiency. J Pediatr Endocrinol Metab. Feb. Suppl 2. 2004;17:267-71. [pmid: 15116950].
9 Betz CL, Redcay G. Creating Healthy Futures: an innovative nurse-managed transition clinic for adolescents and young adults with special health care needs. Pediatr Nurs. Jan-Feb. 2003;29(1):25-30. [pmid: 12630502].
10 Amaria K, Stinson J, Cullen-Dean G, et al. Tools for addressing systems issues in transition. Healthc Q. Oct. 14. 2011;(Spec No 3):72-6. [pmid: 22008577].
11 Paone MC, Wigle M, Saewyc E. The ON TRAC model for transitional care of adolescents. Prog Transplant. Dec. 2006;16(4):291-302. [pmid: 17183935].
12 Kaufmann Rauen K, Sawin KJ, Bartelt T, et al. Transitioning adolescents and young adults with a chronic health condition to adult healthcare - an exemplar program. Rehabil Nurs. Mar-Apr. 2013;38(2):63-72. [pmid: 23529944].
13 Stewart D, Freeman M, Law M, et al. The best journey to adult life for youth with disabilities. An evidence-based model and best practice guidelines for the transition to adulthood. McMaster University, Hamilton Ontario. CanHealth Centre for Childhood Disability Research. 2009. http://transitions.canchild.ca/en/OurResearch/bestpractices.asp.
14 Smith GM, Lewis VR, Whitworth E, et al. Growing up with sickle cell disease: a pilot study of a transition program for adolescents with sickle cell disease. J Pediatr Hematol Oncol. Jul. 2011;33(5):379-82. [pmid: 21602723].
15 Vanelli M, Caronna S, Adinolfi B, et al. Effectiveness of an uninterrupted procedure to transfer adolescents with Type 1 diabetes from the Paediatric to the Adult Clinic held in the same hospital: eight-year experience with the Parma protocol. Diabetes Nutr Metab. Oct. 2004;17(5):304-8. [pmid: 16295053].
16 Chaudhry SR, Keaton M, Nasr SZ. Evaluation of a cystic fibrosis transition program from pediatric to adult care. Pediatr Pulmonol. Jul. 2013;48(7):658-65. [pmid: 22888094].
17 Gerber BS, Solomon MC, Shaffer TL, et al. Evaluation of an internet diabetes self-management training program for adolescents and young adults. Diabetes Technol Ther. Feb. 2007;9(1):60-7. [pmid: 17316099].
18 Maslow G, Adams C, Willis M, et al. An evaluation of a positive youth development program for adolescents with chronic illness. J Adolesc Health. Feb. 2013;52(2):179-85. [pmid: 23332482].
19 Van Walleghem N, MacDonald CA, Dean HJ. Building connections for young adults with type 1 diabetes mellitus in Manitoba: feasibility and acceptability of a transition initiative. Chronic Dis Can. 2006;27(3):130-4. [pmid: 17306065].
20 Van Walleghem N, Macdonald CA, Dean HJ. Evaluation of a systems navigator model for transition from pediatric to adult care for young adults with type 1 diabetes. Diabetes Care. Aug. 2008;31(8):1529-30. [pmid: 18458141].
21 Hankins JS, Osarogiagbon R, Adams-Graves P, et al. A transition pilot program for adolescents with sickle cell disease. J Pediatr Health Care. Nov-Dec. 2012;26(6):e45-9. [pmid: 22819193].
22 Chaturvedi S, Jones CL, Walker RG, et al. The transition of kidney transplant recipients: a work in progress. Pediatr Nephrol. May. 2009;24(5):1055-60. [pmid: 19238453].
23 Craig SL, Towns S, Bibby H. Moving on from paediatric to adult health care: an initial evaluation of a transition program for young people with cystic fibrosis. Int J Adolesc Med Health. Jul-Sep. 2007;19(3):333-43. [pmid: 17937150].
24 Bryon M, Madge S. Transition from paediatric to adult care: psychological principles. J R Soc Med. Suppl 40. 2001;94:5-7. [pmid: 11601164].
25 Price CS, Corbett S, Lewis-Barned N, et al. Implementing a transition pathway in diabetes: a qualitative study of the experiences and suggestions of young people with diabetes. Child Care Health Dev. Nov. 2011;37(6):852-60. [pmid: 22007985].
26 Gleeson H, Davis J, Jones J, et al. The challenge of delivering endocrine care and successful transition to adult services in adolescents with congenital adrenal hyperplasia: experience in a single centre over 18 years. Clin Endocrinol (Oxf). Jan. 2013;78(1):23-8. [pmid: 23009615].
27 Bent N, Tennant A, Swift T, et al. Team approach versus ad hoc health services for young people with physical disabilities: a retrospective cohort study. Lancet. Oct. 26. 2002;360(9342):1280-6. [pmid: 12414202].