# Screening Forms

Table B-1 Abstract screening form

Table B-2 Full text screening form