# Literature Search Strategies

Table A-1 Search strategy and results from PubMed (updated 9/5/2013)

Search Terms | | Search Results
#1 | “Continuity of Patient Care”[mh:noexp] OR “Transition to Adult Care”[mh] OR transition[tiab] OR transitions[tiab] OR transitioning[tiab] OR transitional[tiab] | 247658
#2 | care[tiab] OR “healthcare”[tiab] OR “Health Services”[mh] OR “Health Services Research”[mh] OR “Health Services Accessibility”[mh] OR “Health Services Needs and Demand”[mh] OR “health services”[tiab] OR “Health Planning”[mh:noexp] OR “Patient Care Planning”[mh] OR “pediatric to adult”[tiab] OR “child to adult”[tiab] | 2141964
#3 | Adolescent[mh] OR youth[tiab] OR Child[mh] OR pediatric[tiab] OR paediatric[tiab] OR child[tiab] OR children[tiab] OR adolescent[tiab] OR adolescents[tiab] OR adolescence[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenager[tiab] OR teenagers[tiab] OR “Child Health Services”[mh] OR “Adolescent Health Services”[mh] OR “young people”[tiab] | 2594321
#4 | Adult[mh] OR adult[tiab] OR adults[tiab] OR adulthood[tiab] | 5690952
#5 | “Chronic Disease”[mh] OR “special needs”[tiab] OR “special healthcare needs”[tiab] OR “special health care needs”[tiab] OR “special health needs”[tiab] OR “Disabled Children”[mh] OR disability[tiab] OR disabled[tiab] OR “YSHCN”[tiab] OR “CSHCN”[tiab] OR “chronic disease”[tiab] OR “chronic illness”[tiab] OR “chronic diseases”[tiab] OR “Mental Disorders”[mh] OR “mental illness”[tiab] OR “attention deficit”[tiab] OR depression[tiab] OR anxiety[tiab] OR “conduct disorders”[tiab] OR autism[tiab] OR autistic[tiab] OR Asperger[tiab] OR Asperger's[tiab] OR “pervasive development disorders”[tiab] OR “Developmental Disabilities”[mh] OR “developmental delay”[tiab] OR “developmental delays”[tiab] OR “Intellectual Disability”[mh] OR “intellectual disabilities”[tiab] OR “mental retardation”[tiab] OR “mentally retarded”[tiab] OR asthma[mh] OR asthma*[tiab] OR diabetes[tiab] OR diabetic[tiab] OR “Diabetes Mellitus”[mh] OR Epilepsy[mh] OR “seizure disorders”[tiab] OR “seizure disorder”[tiab] OR epilepsy[tiab] OR “Headache Disorders”[mh] OR migraine*[tiab] OR “Brain Injuries”[mh] OR “traumatic brain injury”[tiab] OR “traumatic brain injuries”[tiab] OR concussion*[tiab] OR “Heart Defects, Congenital”[mh] OR “congenital heart disease”[tiab] OR “congenital heart defects”[tiab] OR “Hematologic Diseases”[mh] OR “blood disorders”[tiab] OR “sickle cell”[tiab] OR anemia[tiab] OR “HIV”[tiab] OR “HIV Infections”[mh] OR “Organ Transplantation”[mh] OR “transplant recipients”[tiab] OR “Deafness”[mh] OR “Blindness”[mh] OR deaf[tiab] OR blind[tiab] OR “Cystic Fibrosis”[mh] OR “cystic fibrosis”[tiab] OR “Cerebral Palsy”[mh] OR “cerebral palsy”[tiab] OR “Muscular Dystrophies”[mh] OR “muscular dystrophy”[tiab] OR “Down Syndrome”[mh] OR “Joint Diseases”[mh] OR arthritis[tiab] OR “functional disability”[tiab] OR “functional disabilities”[tiab] OR “Congenital, Hereditary, and Neonatal Diseases and Abnormalities”[mh] OR “congenital disease”[tiab] OR “congenital diseases”[tiab] OR “congenital defects”[tiab] OR “spina bifida”[tiab] OR “Crohn Disease”[tiab] OR Crohn[tiab] OR “Celiac Disease”[mh] OR celiac[tiab] OR “genetic disease”[tiab] OR “genetic disorder”[tiab] OR “genetic disorders”[tiab] OR “genetic diseases”[tiab] | 4049292
#6 | #1 AND #2 AND #3 AND #4 AND #5 NOT (comment[pt] OR letter[pt] OR editorial[pt] OR news[pt] OR patient education handout[pt] OR legal cases[pt] OR newspaper article[pt] OR news[pt] OR historical article[pt] OR jsubsetk) | 1878
#7 | #6 AND English[la] AND humans[mh] | 1656
#8 | #7 AND (“2000/01/01”[dp] : “3000/12/31”[dp]) | 1373

Key: [tiab] title or abstract word; [th] therapy; [la] language; [mh] medical subject heading; [pt] publication type; “jsubsetk” consumer health journal subset