# Summary and Implications

Existing evidence suggests that many needs of cancer survivors are unmet and that many cancer programs do not deliver any type of formal survivorship that might address these needs.11,14

An overarching theme across the literature and KI interviews relates to the heterogeneity of existing practice and nascent research addressing these issues. Our systematic review of the evaluations of existing programs for the Technical Brief classified interventions into four categories: nurse-led, physician-led, SCP-centered, and individual or group counseling models. Within each category, we found substantial variation in the types of cancers; timing, components, intensity, and followup of care delivery; and types of outcomes evaluated. Although this report only includes studies of individuals who had completed active treatment, substantial heterogeneity also exists in how the field defines a “cancer survivor” and how survivor needs may differ. Furthermore, there is often substantial heterogeneity in terms of type of cancer and stage at diagnosis among survivors included in studies of a single model of survivorship care. Examining the outcomes of models for more homogeneous groups of survivors will be critical for developing this evidence base.

Another finding is the paucity of evidence regarding fundamental questions such as what constitutes “usual care” for a cancer survivor, what a survivorship care model is, and whether models of cancer survivorship care result in improved outcomes for patients when compared with usual care. As noted in the methods section, we focused on studies that addressed multiple needs of survivors. If we had elected to broaden our focus to studies addressing single needs of survivors, our yield would have been larger, but these studies would not have spoken to the issue of models of care.

A related question is whether programs addressing only two different needs for cancer survivors are sufficiently comprehensive to be considered models. We had discussed defining survivorship care models as programs that addressed all four of the components listed by the IOM, but we identified few studies of survivorship care models even using this expanded (two needs) definition. Other groups (e.g., LIVESTRONG) have also outlined elements of cancer survivorship care that may be used for future development of care programs. However, differences among the specified components of survivorship care from differing sources may also increase model heterogeneity and thus increase challenges in understanding and evaluating care models.

Our findings suggest that models of survivorship care are highly idiosyncratic, or individualized to the institution or organization where they are based; the care provided in these models may depend on the relationship between the provider and the survivor, the setting(s) of care, the type(s) of cancer and cancer treatment(s), the survivor's risks associated with the disease, and the practice setting(s) where survivorship care occurs. Thus, it may be difficult to pull out commonalities among different models. This in and of itself is a gap in the survivorship care knowledge base that needs to be addressed in order to develop and evaluate care models. In addition, current reimbursement rules may disincentivize new care models, so oncologists continue to see cancer survivors. However, an anticipated workforce shortage of oncologists may require new approaches such as the expanded use of nurse practitioners and physician assistants, shared care with primary care providers, and patient navigators. Concerns about these alternatives include payment systems, adequacy of training, and greater fragmentation of care.

## Limitations of This Technical Brief

Because a Technical Brief is intended to provide an overview rather than an exhaustive cataloging of the evidence, it does not capture the entirety of the evidence on every question (as a systematic review would). Due to constraints imposed by the Office of Management and Budget, we were limited to nine or fewer non-Federal key informants. In an emerging area of research with limited published empirical evidence, this constraint limited our ability to achieve a saturation of viewpoints.

Feedback from public review and peer review also raises other limitations. One reviewer noted that the field needs a review of existing survivorship programs and interviews with their directors to evaluate the types of models that currently exist and address their pros and cons. This type of activity is beyond the scope of our product.

Another reviewer noted that one possible limitation was in the KI question guide: the question on harms and disadvantages may not have had an appropriate probe, resulting in few comments on this topic. As a result, we may not have elicited information on harms such as allocation of resources away from curative treatment and additional worry and distress for patients. However, from our literature review, there appears to be little evidence regarding harms associated with survivorship care programs.

## Next Steps

Based on the literature review and interviews with KIs, we identified a number of questions that need to be explored for optimal development of cancer survivor care models. For each question, we provide suggestions for the cancer survivorship community, including survivors, clinical providers, policymakers, and researchers, to address these questions.

1. What is a model of cancer survivorship care? How should models of care be defined or specified to differentiate them from other types of survivorship care services, and from models of care for other conditions (e.g., models for survivors of kidney transplant or traumatic brain injury)? What types of taxonomies and conceptual models will be useful to develop and examine survivorship care models?
  Suggestions for addressing this question: Stakeholders in the cancer survivorship community need to agree on a common definition for “survivorship models” and on a taxonomy for types of models. A meeting with broad participation from key stakeholder groups may be useful for reaching consensus (or at least general agreement) on this topic.
2. In evaluating the outcomes associated with survivorship care models, what should constitute usual care? KIs interviewed for this report generally agreed that currently no standard survivorship care program exists.
  Suggestions for addressing this question: Studies are needed to better understand the current experiences of cancer survivors, particularly those who do not receive followup care at academic centers. This will likely include analyses of existing data sets (e.g., claims data or electronic medical records) as well as focus groups or interviews with survivors, clinical providers, and other stakeholders.
3. What is the most opportune time following completion of active treatment to initiate a survivorship care program? Does this vary based on the type of cancer, stage of cancer at diagnosis, or other patient sociodemographic and clinical characteristics? How does preparation for end-of-treatment transition to survivorship care get incorporated into existing cancer treatment?
4. What is the optimal period for repeated visits or other contacts with cancer survivors? Does this depend on patient sociodemographic or clinical characteristics? Are repeated face-to-face survivorship visits needed or does a one-time visit provide comparable outcomes?
5. What is the optimal followup period for a survivorship care model? What is the minimum period needed to assess the potential impacts of a model? What period is needed to capture a majority of the developments of late effects, recurrences, or new cancers among survivors?
  Suggestions for addressing Questions 3, 4, and 5: Input from cancer survivors is needed regarding changes in their support needs at different periods following completion of active treatment. Clinical providers and researchers developing or implementing survivorship care programs and models need to consider this input and align programs with the needs of survivors from differing periods. Evaluations of survivorship care models should examine differences in outcomes based on time since completion of active treatment and should provide clear information on the time since treatment completion among participants and stratification of outcomes by time since completion. Cancer survivor risk stratification will also affect timing of support needs, although determining risk stratification for survivorship care is also an issue that has not been fully addressed.
  Survivorship care programs need to provide repeated assessments over time of their key outcomes to explore how (or whether) outcomes change with additional followup interactions or increased duration of followup. Similarly, programs need to consider survivors who discontinue participation in programs, including whether participation for an initial period results in longer-term benefits and why survivors choose to discontinue participation. Once a reasonable body of information is available on how survivors' needs and program effectiveness vary by time since completion of active treatment and optimal periods for survivorship contacts and followup of care, recommendations can be developed to guide future models.
6. What minimum set of outcomes should be examined in all studies of survivorship care models and how should they be measured? At present, diverse and largely incompatible outcomes are assessed, presenting barriers to comparisons across differing models. Are new metrics needed to assess crucial elements of survivorship care, such as degree of care coordination versus fragmentation?
  Suggestions for addressing this question: As with Question 1, answering this question likely requires discussions among a broad group of stakeholders in the cancer survivorship community to agree on a minimal set of outcome measures to be assessed by all survivorship care models. Clearly, models may wish to assess additional outcomes that are specific to the survivor population being targeted or the services being offered by a model. However, all models should provide at least an agreed-upon set of common outcome measures. Journals, conferences, and grant-funding organizations could require this information from survivorship care programs and not accept those that are lacking the minimal set of outcomes.
7. For models involving SCPs, what are the key elements to include? What elements of SCPs do survivors and PCPs find most useful? How can programs balance the need to be comprehensive in the information provided versus overloading survivors with too much information?
  Suggestions for addressing this question: A substantial body of literature exists regarding SCPs. Compiling a compendium of this literature and identifying and comparing the specific elements included in each SCP would provide a useful resource. Input from survivors as to the components of SCPs that were (or were not) useful will also be key. Certain elements will be required for all SCPs, such as details of the diagnosis and treatments received and recommended surveillance. However, future programs or models involving SCPs may want to explore including different subsets of SCP elements in two or more participant groups to assess the impacts of these elements on outcomes among survivors and their clinical providers.
8. How do survivorship care models differ with respect to resource utilization, cost, cost-effectiveness, and efficiency? Are some models more advantageous in settings with limited resources or finances? What resources are needed to implement different models of care? How do varying payment systems affect receipt of survivorship care?
  Suggestions for addressing this question: As discussed repeatedly in this report, cancer survivorship models display tremendous heterogeneity. Therefore, at the present time, comparisons of resource utilization, cost, cost-effectiveness, and efficiency among survivorship models are not feasible; the resource utilization and costs from a model are likely not generalizable across survivor populations, settings, and model types. As survivor models adopt more common practices and outcome measures, comparisons of resource utilization and costs may become more feasible. Investigating the impact of payment systems on receipt of survivorship care may be currently feasible; that is, do variations in payment system influence the likelihood of receiving survivorship care services?
9. How should models be tailored to optimally benefit survivors from underserved populations, including those from racial/ethnic minorities, low socioeconomic status, older age groups, and low health literacy?
  Suggestions for addressing this question: Most of the models examined for this report either included low numbers of survivors from underserved populations or did not report the proportion of underserved individuals participating. Survivorship care models should focus more strongly on recruitment and outreach to attract survivor populations that reflect the overall population of adults treated for cancer. In addition, the models we examined were largely based at academic centers or hospitals with substantial research experience. Models based in settings that focus on survivor care for underserved populations, such as Federally Qualified Health Centers or rural locations, are needed to collect information from and develop approaches tailored for these vulnerable groups.