# References

1 Mariotto AB, Yabroff KR, Shao Y, et al. Projections of the cost of cancer care in the United States: 2010-2020. J Natl Cancer Inst. Jan. 19. 2011;103(2):117-28. [pmid: 21228314].
2 Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2009 (Vintage 2009 Populations). National Cancer Institute. Bethesda, MD. 2012. http://seer.cancer.gov/csr/1975_2009_pops09/, based on November 2011 SEER data submission, posted to the SEER Web site, April 2012.
3 Erikson C, Salsberg E, Forte G, et al. Future supply and demand for oncologists: challenges to assuring access to oncology services. J Oncol Pract. Mar. 2007;3(2):79-86. [pmid: 20859376].
4 Towle E, Hanley A. Examining the role of nonphysician practitioners in oncology practice. Am Soc Clin Oncol Ed Book. 2011:417-9.
5 Cavallo J. ASCO reexamines the oncology workforce shortage. The ASCO Post. 2012;3(9).
6 Aziz NM. Cancer survivorship research: state of knowledge, challenges and opportunities. Acta Oncol. 2007;46(4):417-32. [pmid: 17497308].
7 National Research Council. From Cancer Patient to Cancer Survivor: Lost in Transition. Washington, DC. The National Academies Press. 2005.
8 Potosky AL, Han PK, Rowland J, et al. Differences between primary care physicians' and oncologists' knowledge, attitudes and practices regarding the care of cancer survivors. J Gen Intern Med. Dec. 2011;26(12):1403-10. [pmid: 21785923].
9 Forsythe LP, Alfano CM, Leach CR, et al. Who provides psychosocial follow-up care for post-treatment cancer survivors? A survey of medical oncologists and primary care physicians. J Clin Oncol. Aug. 10. 2012;30(23):2897-905. [pmid: 22778322].
10 Cheung WY, Neville BA, Cameron DB, et al. Comparisons of patient and physician expectations for cancer survivorship care. J Clin Oncol. May. 20. 2009;27(15):2489-95. [pmid: 19332716].
11 Nicolaije KA, Husson O, Ezendam NP, et al. Endometrial cancer survivors are unsatisfied with received information about diagnosis, treatment and follow-up: A study from the population-based PROFILES registry. Patient Educ Couns. Sep. 2012;88(3):427-35. [pmid: 22658248].
12 Mallinger JB, Griggs JJ, Shields CG. Patient-centered care and breast cancer survivors' satisfaction with information. Patient Educ Couns. Jun. 2005;57(3):342-9. [pmid: 15893218].
13 Husson O, Holterhues C, Mols F, et al. Melanoma survivors are dissatisfied with perceived information about their diagnosis, treatment and follow-up care. Br J Dermatol. Oct. 2010;163(4):879-81. [pmid: 20854404].
14 Chubak J, Tuzzio L, Hsu C, et al. Providing Care for Cancer Survivors in Integrated Health Care Delivery Systems: Practices, Challenges, and Research Opportunities. J Oncol Pract. 2012;8(3):184-9. [pmid: 22942814].
15 Birken SA, Mayer DK, Weiner BJ. Survivorship care plans: prevalence and barriers to use. J Cancer Educ. Jun. 2013;28(2):290-6. [pmid: 23526552].
16 United States Senate. Title I-Quality, Affordable Health Care for all Americans. Washington, DC. United States Government Printing Office. 2009. www.healthcare.gov/law/full/patient-protection.pdf. January 21, 2014.
17 Greenapple R. Accountable care organizations: implications for oncologists. 2011. www.valuebasedcancer.com/article/accountable-care-organizations-implications-oncologists. February 6, 2013.
18 Gilbert SM, Miller DC, Hollenbeck BK, et al. Cancer survivorship: challenges and changing paradigms. J Urol. Feb. 2008;179(2):431-8. [pmid: 18076919].
19 Hypnosis helps reduce hot flashes in breast cancer survivors. Harv Womens Health Watch. Feb. 2009;16(6):3. [pmid: 19297743].
20 Amsterdam A, Krychman ML. Sexual dysfunction in patients with gynecologic neoplasms: a retrospective pilot study. J Sex Med. Jul. 2006;3(4):646-9. [pmid: 16776780].
21 Ashing-Giwa KT. Enhancing physical well-being and overall quality of life among underserved Latina-American cervical cancer survivors: feasibility study. J Cancer Surviv. Sep. 2008;2(3):215-23. [pmid: 18712607].
22 Benton B, Norton C, Lindsay JO, et al. Can nurses manage gastrointestinal symptoms arising from pelvic radiation disease?. Clin Oncol (R Coll Radiol). Oct. 2011;23(8):538-51. [pmid: 21530194].
23 Butt CM. Hope in patients with cancer transitioning to survivorship: the mid-life directions workshop as a supportive intervention. Oncol Nurs Forum. May. 1. 2012;39(3):E269-74. [pmid: 22543398].
24 Angell KL, Kreshka MA, McCoy R, et al. Psychosocial intervention for rural women with breast cancer: The Sierra-Stanford Partnership. J Gen Intern Med. Jul. 2003;18(7):499-507. [pmid: 12848832].
25 Heidrich SM, Brown RL, Egan JJ, et al. An individualized representational intervention to improve symptom management (IRIS) in older breast cancer survivors: three pilot studies. Oncol Nurs Forum. May. 2009;36(3):E133-43. [pmid: 19403441].
26 Hundepool AC, Dumans AG, Hofer SO, et al. Rehabilitation after mandibular reconstruction with fibula free-flap: clinical outcome and quality of life assessment. Int J Oral Maxillofac Surg. Nov. 2008;37(11):1009-13. [pmid: 18657394].
27 Park JH, Bae SH, Jung YS, et al. Quality of life and symptom experience in breast cancer survivors after participating in a psychoeducational support program: a pilot study. Cancer Nurs. Jan-Feb. 2012;35(1):E34-41. [pmid: 21760491].
28 Pekmezi DW, Demark-Wahnefried W. Updated evidence in support of diet and exercise interventions in cancer survivors. Acta Oncol. 2011;50(2):167-78. [pmid: 21091401].
29 Schultz DM, Mir M. Cancer180: because when cancer strikes, life does a 180. Psycho-Oncol. 2012;21:7.
30 Sherman KA, Heard G, Cavanagh KL. Psychological effects and mediators of a group multi-component program for breast cancer survivors. J Behav Med. Oct. 2010;33(5):378-91. [pmid: 20502954].
31 Shields CG, Ziner KW, Bourff SA, et al. An intervention to improve communication between breast cancer survivors and their physicians. J Psychosoc Oncol. Nov. 2010;28(6):610-29. [pmid: 21058159].
32 Vallance JK, Courneya KS, Plotnikoff RC, et al. Analyzing theoretical mechanisms of physical activity behavior change in breast cancer survivors: results from the activity promotion (ACTION) trial. Ann Behav Med. Apr. 2008;35(2):150-8. [pmid: 18347895].
33 Vallance JK, Courneya KS, Plotnikoff RC, et al. Randomized controlled trial of the effects of print materials and step pedometers on physical activity and quality of life in breast cancer survivors. J Clin Oncol. Jun. 10. 2007;25(17):2352-9. [pmid: 17557948].
34 Campbell KL, Van Patten CL, Neil SE, et al. Feasibility of a lifestyle intervention on body weight and serum biomarkers in breast cancer survivors with overweight and obesity. J Acad Nutr Diet. Apr. 2012;112(4):559-67. [pmid: 22709706].
35 Glynne-Jones R, Chait I, Thomas SF. When and how to discharge cancer survivors in long term remission from follow-up: the effectiveness of a contract. Clin Oncol (R Coll Radiol). 1997;9(1):25-9. [pmid: 9039810].
36 Grunfeld E, Levine MN, Julian JA, et al. Randomized trial of long-term follow-up for early-stage breast cancer: a comparison of family physician versus specialist care. J Clin Oncol. Feb. 20. 2006;24(6):848-55. [pmid: 16418496].
37 Kinney CK, Rodgers DM, Nash KA, et al. Holistic healing for women with breast cancer through a mind, body, and spirit self-empowerment program. J Holist Nurs. Sep. 2003;21(3):260-79. [pmid: 14528850].
38 Kwok C, Ho M. Development and evaluation of a culturally sensitive support group programme for Chinese-Australian women with breast cancer: a pilot study. Eur J Cancer Care (Engl). Nov. 2011;20(6):795-802. [pmid: 21771132].
39 van Weert E, May AM, Korstjens I, et al. Cancer-related fatigue and rehabilitation: a randomized controlled multicenter trial comparing physical training combined with cognitive-behavioral therapy with physical training only and with no intervention. Phys Ther. Oct. 2010;90(10):1413-25. [pmid: 20651011].
40 Waltman NL, Twiss JJ, Ott CD, et al. Testing an intervention for preventing osteoporosis in postmenopausal breast cancer survivors. J Nurs Scholarsh. 2003;35(4):333-8. [pmid: 14735675].
41 Waltman NL, Twiss JJ, Ott CD, et al. The effect of weight training on bone mineral density and bone turnover in postmenopausal breast cancer survivors with bone loss: a 24-month randomized controlled trial. Osteoporos Int. Aug. 2010;21(8):1361-9. [pmid: 19802506].
42 Zibecchi L, Greendale GA, Ganz PA. Comprehensive menopausal assessment: an approach to managing vasomotor and urogenital symptoms in breast cancer survivors. Oncol Nurs Forum. 2003;30(3):393-407. [pmid: 12719740].
43 Oeffinger KC, McCabe MS. Models for delivering survivorship care. J Clin Oncol. Nov. 10. 2006;24(32):5117-24. [pmid: 17093273].
44 McCabe MS, Bhatia S, Oeffinger KC, et al. American Society of Clinical Oncology statement: achieving high-quality cancer survivorship care. J Clin Oncol. Feb. 10. 2013;31(5):631-40. [pmid: 23295805].
45 Harrop JP, Dean JA, Paskett ED. Cancer survivorship research: a review of the literature and summary of current NCI-designated cancer center projects. Cancer Epidemiol Biomarkers Prev. Oct. 2011;20(10):2042-7. [pmid: 21980012].
46 Forsythe LP, Parry C, Alfano CM, et al. Gaps in survivorship care plan delivery and potential benefits to survivorship care. J Clin Oncol. 2013;31(15).
47 Stark JC. Perceived benefits of group music therapy for breast cancer survivors: Mood, psychosocial well-being, and quality of life. [Dissertation]. Ann Arbor. Michigan State University. 2012.
48 Aschwanden C. For cancer patients, rehab can start even before treatment does. Washington Post. July. 2013;30:2013.
49 Avino RJ, Allam ES, Chen L, et al. Breast cancer patient surveillance following curative-intent treatment: variation among metropolitan statistical areas. J Clin Oncol. 2013;31(15).
50 Avino RJ, Margenthaler JA, Allam ES, et al. Patient surveillance after breast cancer treatment: variation among metropolitan statistical areas. J Surg Res. 2013;179(2).
51 Blair CK, Madan-Swain A, Locher JL, et al. Harvest for health gardening intervention feasibility study in cancer survivors. Acta Oncol. 2013;52(6):1110-8. [pmid: 23438359].
52 Brothers BM, Easley A, Salani R, et al. Do survivorship care plans impact patients' evaluations of care? A randomized evaluation with gynecologic oncology patients. Gynecol Oncol. Jun. 2013;129(3):554-8. [pmid: 23474344].
53 Burke CA. Younger Women with Breast Cancer: The Impact of Self-Directed Learning on Quality of Life during Chemotherapy [D.B.A.]. Ann Arbor. Wilmington University (Delaware). 2013.
54 Caceres A. Adverse changes in body composition of cancer survivors with BRCA mutations. J Clin Oncol. 2013;31(15).
55 Calip GS, Boudreau DM, Loggers ET. Changes in adherence to statins and subsequent lipid profiles during and following breast cancer treatment. Breast Cancer Res Treat. 2013;138(1):225-33. [pmid: 23358904].
56 Farrugia P, Petrisor BA, Farrokhyar F, et al. Practical tips for surgical research: Research questions, hypotheses and objectives. Can J Surg. Aug. 2010;53(4):278-81. [pmid: 20646403].
57 Campbell MK, Tessaro I, Gellin M, et al. Adult cancer survivorship care: experiences from the LIVESTRONG Centers of Excellence Network. J Cancer Surviv. Sep. 2011;5(3):271-82. [pmid: 21553353].
58 McCabe MS, Jacobs LA. Clinical update: survivorship care–models and programs. Semin Oncol Nurs. Aug. 2012;28(3):e1-8. [pmid: 22846488].
59 Howell D, Hack TF, Oliver TK, et al. Survivorship services for adult cancer populations: a pan-Canadian guideline. Curr Oncol. 2011;18(6):e265-e81. [pmid: 22184494].
60 Flood KL, Carroll MB, Le CV, et al. Polypharmacy in hospitalized older adult cancer patients: experience from a prospective, observational study of an oncology-acute care for elders unit. Am J Geriatr Pharmacother. Jun. 2009;7(3):151-8. [pmid: 19616183].
61 Rechis R, Beckjord EB, Arvey SR, et al. The Essential Elements of Survivorship Care: A LiveSTRONG Brief. The National Cancer Survivorship Resource Center, American Cancer Society, and The GW Cancer Institute-The George Washington University funded by Centers for Disease Control and Prevention Cooperative Agreement #1U55DP003054. 2011. https://assets-livestrong-org.s3.amazonaws.com/media/site_proxy/data/7e26de7ddcd2b7ace899e75f842e50c0075c4330.pdf. November 11, 2013.
62 Jefford M, Lotfi-Jam K, Baravelli C, et al. Development and pilot testing of a nurse-led posttreatment support package for bowel cancer survivors. Cancer Nurs. May-Jun. 2011;34(3):E1-10. [pmid: 21045754].
63 Naumann F, Munro A, Martin E, et al. An individual-based versus group-based exercise and counselling intervention for improving quality of life in breast cancer survivors. A feasibility and efficacy study. Psychooncology. Oct. 2012;21(10):1136-9. [pmid: 21726017].
64 Verbeek J, Spelten E, Kammeijer M, et al. Return to work of cancer survivors: a prospective cohort study into the quality of rehabilitation by occupational physicians. Occup Environ Med. May. 2003;60(5):352-7. [pmid: 12709521].
65 Casillas J, Syrjala KL, Ganz PA, et al. How confident are young adult cancer survivors in managing their survivorship care? A report from the LIVESTRONG Survivorship Center of Excellence Network. J Cancer Surviv. Dec. 2011;5(4):371-81. [pmid: 22042661].
66 Miedema B, Easley J, Robinson LM. Do current cancer follow-up care practices meet the needs of young adult cancer survivors in Canada? A qualitative inquiry. Curr Oncol. 2013;20(1):14-22. [pmid: 23443642].
67 Cox A, Faithfull S. ‘They're survivors physically but we want them to survive mentally as well': health care professionals’ views on providing potential late effect information. Support Care Cancer. 2013;21(9):2491-7. [pmid: 23609926].
68 Aebi S, Davidson T, Gruber G, et al. Primary breast cancer: ESMO Clinical Practice Guidelines for diagnosis, treatment and follow-up. Ann Oncol. May. 2010;21(Supplement 5):v9-14. [pmid: 20555111].
69 Heidenreich A, Bolla M, Joniau S, et al. Guidelines on Prostate Cancer. European Association of Urology. 2011.
70 Earle C, Annis R, Sussman J, et al. Follow-up care, surveillance protocol, and secondary prevention measures for survivors of colorectal cancer. Cancer Care Ontario Program in Evidence-based Care Evidence-Based Series No.: 26-2. Toronto, ON. Feb. 3. 2012.
71 Baird J, Belchamber C, Bellamy D, et al. The diagnosis and treatment of lung cancer. National Health Service. 2005.
72 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology (NCCN Guidelines): Survivorship [Presentation]. 2013. http://www.jnccn.org/content/11/5S/640.full. June 11, 2013.
73 Wood L, Wilke D, Rendon R, et al. Management of Prostate Cancer - Comprehensive Version. Cancer Care Nova Scotia. 2006.
74 Fillion L, Gagnon P, Leblond F, et al. A brief intervention for fatigue management in breast cancer survivors. Cancer Nurs. Mar-Apr. 2008;31(2):145-59. [pmid: 18490891].
75 Espie CA, Fleming L, Cassidy J, et al. Randomized controlled clinical effectiveness trial of cognitive behavior therapy compared with treatment as usual for persistent insomnia in patients with cancer. J Clin Oncol. Oct. 1. 2008;26(28):4651-8. [pmid: 18591549].
76 Dirksen SR, Epstein DR. Efficacy of an insomnia intervention on fatigue, mood and quality of life in breast cancer survivors. J Adv Nurs. Mar. 2008;61(6):664-75. [pmid: 18302607].
77 Bloom JR, Stewart SL, D'Onofrio CN, et al. Addressing the needs of young breast cancer survivors at the 5 year milestone: can a short-term, low intensity intervention produce change?. J Cancer Surviv. Sep. 2008;2(3):190-204. [pmid: 18670888].
78 Meneses KD, McNees P, Loerzel VW, et al. Transition from treatment to survivorship: effects of a psychoeducational intervention on quality of life in breast cancer survivors. Oncol Nurs Forum. Sep. 2007;34(5):1007-16. [pmid: 17878129].
79 Epstein DR, Dirksen SR. Randomized trial of a cognitive-behavioral intervention for insomnia in breast cancer survivors. Oncol Nurs Forum. Sep. 2007;34(5):E51-9. [pmid: 17878117].
80 Campbell LC, Keefe FJ, Scipio C, et al. Facilitating research participation and improving quality of life for African American prostate cancer survivors and their intimate partners. A pilot study of telephone-based coping skills training. Cancer. Jan. 15. 2007;109(2 Suppl):414-24. [pmid: 17173280].
81 Gielissen MF, Verhagen S, Witjes F, et al. Effects of cognitive behavior therapy in severely fatigued disease-free cancer patients compared with patients waiting for cognitive behavior therapy: a randomized controlled trial. J Clin Oncol. Oct. 20. 2006;24(30):4882-7. [pmid: 17050873].
82 Harrison SE, Watson EK, Ward AM, et al. Cancer survivors' experiences of discharge from hospital follow-up. Eur J Cancer Care (Engl). May. 2012;21(3):390-7. [pmid: 22092880].
83 Jones JM, Ferguson S, Edwards E, et al. Experiences of care delivery: endometrial cancer survivors at end of treatment. Gynecol Oncol. Mar. 2012;124(3):458-64. [pmid: 22079362].
84 Cheung WY, Neville BA, Earle CC. Associations among cancer survivorship discussions, patient and physician expectations, and receipt of follow-up care. J Clin Oncol. May. 20. 2010;28(15):2577-83. [pmid: 20406932].
85 Haggstrom DA, Arora NK, Helft P, et al. Follow-up care delivery among colorectal cancer survivors most often seen by primary and subspecialty care physicians. J Gen Intern Med. Nov. Suppl 2. 2009;24:S472-9. [pmid: 19838853].
86 Kantsiper M, McDonald EL, Geller G, et al. Transitioning to Breast Cancer Survivorship: Perspectives of Patients, Cancer Specialists, and Primary Care Providers. J Gen Intern Med. 2009;24:459-66.
87 Absolom K, Eiser C, Michel G, et al. Follow-up care for cancer survivors: views of the younger adult. Br J Cancer. Aug. 18. 2009;101(4):561-7. [pmid: 19638979].
88 Mayer EL, Gropper AB, Neville BA, et al. Breast cancer survivors' perceptions of survivorship care options. J Clin Oncol. Jan. 10. 2012;30(2):158-63. [pmid: 22162585].
89 Brennan ME, Butow P, Marven M, et al. Survivorship care after breast cancer treatment–experiences and preferences of Australian women. Breast. Jun. 2011;20(3):271-7. [pmid: 21236671].
90 Marbach TJ, Griffie J. Patient preferences concerning treatment plans, survivorship care plans, education, and support services. Oncol Nurs Forum. May. 2011;38(3):335-42. [pmid: 21531683].
91 Del Giudice ME, Grunfeld E, Harvey BJ, et al. Primary care physicians' views of routine follow-up care of cancer survivors. J Clin Oncol. Jul. 10. 2009;27(20):3338-45. [pmid: 19380442].
92 Collins RF, Bekker HL, Dodwell DJ. Follow-up care of patients treated for breast cancer: a structured review. Cancer Treat Rev. Feb. 2004;30(1):19-35. [pmid: 14766124].
93 Snyder CF, Earle CC, Herbert RJ, et al. Trends in follow-up and preventive care for colorectal cancer survivors. J Gen Intern Med. Mar. 2008;23(3):254-9. [pmid: 18197456].
94 Hill-Kayser CE, Vachani C, Hampshire MK, et al. High level use and satisfaction with internet-based breast cancer survivorship care plans. Breast J. Jan-Feb. 2012;18(1):97-9. [pmid: 22098063].
95 Hill-Kayser CE, Vachani C, Hampshire MK, et al. An internet tool for creation of cancer survivorship care plans for survivors and health care providers: design, implementation, use and user satisfaction. J Med Internet Res. 2009;11(3):e39. [pmid: 19734128].
96 Barg FK, Cronholm PF, Straton JB, et al. Unmet psychosocial needs of Pennsylvanians with cancer: 1986-2005. Cancer. Aug. 1. 2007;110(3):631-9. [pmid: 17592828].
97 Becker H, Rechis R, Kang SJ, et al. The post-treatment experience of cancer survivors with pre-existing cardiopulmonary disease. Support Care Cancer. Sep. 2011;19(9):1351-5. [pmid: 20658347].
98 Walton LM, Reeve J, Brown PM, et al. Gynaecologic cancer patients' needs and experiences of supportive health services in New Zealand. Psychooncology. Feb. 2010;19(2):201-8. [pmid: 19253918].
99 Binkley JM, Harris SR, Levangie PK, et al. Patient perspectives on breast cancer treatment side effects and the prospective surveillance model for physical rehabilitation for women with breast cancer. Cancer. Apr. 15. 2012;118(8 Suppl):2207-16. [pmid: 22488695].
100 Cappiello M, Cunningham RS, Knobf MT, et al. Breast cancer survivors: information and support after treatment. Clin Nurs Res. Nov. 2007;16(4):278-93. discussion 94-301. [pmid: 17991908].
101 Kent EE, Arora NK, Rowland JH, et al. Health information needs and health-related quality of life in a diverse population of long-term cancer survivors. Patient Educ Couns. Nov. 2012;89(2):345-52. [pmid: 23021856].
102 Burg MA, Lopez EDS, Dailey A, et al. The Potential of Survivorship Care Plans in Primary Care Follow-up of Minority Breast Cancer Patients. J Gen Intern Med. 2009;24:467-71.
103 Smith AW, Reeve BB, Bellizzi KM, et al. Cancer, comorbidities, and health-related quality of life of older adults. Health Care Financ Rev. Summer. 2008;29(4):41-56. [pmid: 18773613].
104 Kokko R, Hakama M, Holli K. Follow-up cost of breast cancer patients with localized disease after primary treatment: a randomized trial. Breast Cancer Res Treat. Oct. 2005;93(3):255-60. [pmid: 16132530].
105 Hong S, Nekhlyudov L, Didwania A, et al. Cancer survivorship care: exploring the role of the general internist. J Gen Intern Med. Nov. Suppl 2. 2009;24:S495-500. [pmid: 19838857].
106 Cannon AJ, Darrington DL, McIlvain HE, et al. Association of number of follow-up providers with outcomes in survivors of hematologic malignancies. Leuk Lymphoma. Oct. 2010;51(10):1862-9. [pmid: 20858098].
107 Wattchow DA, Weller DP, Esterman A, et al. General practice vs surgical-based follow-up for patients with colon cancer: randomised controlled trial. Br J Cancer. Apr. 24. 2006;94(8):1116-21. [pmid: 16622437].
108 Knowles G, Sherwood L, Dunlop MG, et al. Developing and piloting a nurse-led model of follow-up in the multidisciplinary management of colorectal cancer. Eur J Oncol Nurs. Jul. 2007;11(3):212-23. discussion 24-7. [pmid: 17188938].
109 Gates P, Seymour JF, Krishnasamy M. Insights into the development of a nurse-led survivorship care intervention for long-term survivors of Hodgkin lymphoma. Aust J Can Nurs. Jun. 2012;13(1):4-10.
110 Curcio KR, Lambe C, Schneider S, et al. Evaluation of a cancer survivorship protocol: transitioning patients to survivors. Clin J Oncol Nurs. Aug. 2012;16(4):400-6. [pmid: 22842691].
111 Grunfeld E, Julian JA, Pond G, et al. Evaluating survivorship care plans: results of a randomized, clinical trial of patients with breast cancer. J Clin Oncol. Dec. 20. 2011;29(36):4755-62. [pmid: 22042959].
112 Salz T, Oeffinger KC, McCabe MS, et al. Survivorship care plans in research and practice. CA Cancer J Clin. Jan. 12. 2012;62(2):101-17. [pmid: 22241452].
113 Murthy VH, Krumholz HM, Gross CP. Participation in cancer clinical trials: race-, sex-, and age-based disparities. JAMA. Jun. 9. 2004;291(22):2720-6. [pmid: 15187053].
114 Banda DR, Libin AV, Wang H, et al. A pilot study of a culturally targeted video intervention to increase participation of African American patients in cancer clinical trials. Oncologist. May. 2012;17(5):708-14. [pmid: 22639112].
115 Scott DA, Mills M, Black A, et al. Multidimensional rehabilitation programmes for adult cancer survivors. Cochrane Database of Systematic Reviews. 2013;(3).
116 Jefford M, Rowland J, Grunfeld E, et al. Implementing improved post-treatment care for cancer survivors in England, with reflections from Australia, Canada and the USA. Br J Cancer. 2013;108(1):14-20. [pmid: 23257892].
117 Rowland JH, Kent EE, Forsythe LP, et al. Cancer survivorship research in Europe and the United States: Where have we been, where are we going, and what can we learn from each other?. Cancer. Jun. 1. 2013;119(Suppl 11):2094-108. [pmid: 23695922].