# Methods

Systematic reviews require some certainty around definitional issues and a body of studies to advance understanding of important issues. Technical Briefs, by contrast, are appropriate products for nascent fields with large uncertainties around definitional issues and limited or no evidence, precisely because they focus on uncertainties in definition, context, and outcomes. A Technical Brief does not attempt to rate the risk of bias of individual studies or grade the strength of the evidence of the literature. The purpose of a Technical Brief is to provide an overview of key issues related to the intervention such as current indications, relevant patient populations and subgroups of interest, outcomes measured, and contextual factors that may affect decisions regarding the intervention. Technical Briefs integrate discussions with Key Informants (KIs), targeted searches of the published literature and gray literature, and for questions on outcomes, a comprehensive and systematic literature review. Our protocol (available at www.effectivehealthcare.ahrq.gov) describes our a priori decisions and was posted on March 29, 2013.

## Discussions With KIs

In consultation with our team and AHRQ, we identified distinct perspectives that were needed to inform the development of a Technical Brief in this area. Specifically, we sought to recruit the following as KIs: patient advocates, clinical providers (i.e., oncologists) offering survivorship services, primary care providers, nurses, policymakers, management and administration, financing and reimbursement, and researchers.

The KIs were particularly useful for shaping the Technical Brief because little empirical evidence exists about a gold standard model of survivorship care. The KIs contributed to understanding which components of the models are in current use and considered to be most effective across cancer types, where the models might fit into clinical care, and what the potential advantages or concerns are related to developing and implementing these models. Specifically, responses to GQs 1, 2, and 4 are based largely on KI discussions.

The 10 KIs that the Evidence-based Practice Center (EPC) interviewed represented various fields of expertise related to cancer survivorship: patient advocacy (n=2), policy (n=3), management and administration (n=2), financing and reimbursement (n=1), primary care (n=1), and research (n=4); some KIs represented multiple fields of expertise, including oncology practice. Others had personal experience as cancer survivors. More detail about the KI process is available in Appendix A.

## Gray Literature Search

GQs 1, 2, and 4 listed above primarily relied on information from published narrative reviews and information in the gray literature. We used the gray literature (i.e., literature outside the peer-reviewed literature) to identify additional model components that are in piloting stages or not yet fully implemented. We identified 118 nonduplicated citations from the gray literature search.

## Published Literature Search

### Criteria for Inclusion/Exclusion of Studies in the Review

Table 1 lists the inclusion and exclusion criteria in our protocol. Although survivorship encompasses varying stages of the cancer survivor's experience, to try to eliminate any competing effects of active treatments, this report only includes studies of individuals who completed active treatment. Our preliminary inclusion criteria did not constrain included studies based on the comprehensiveness of the services offered. We included all studies that offered at least one of the four core Institute of Medicine (IOM) survivorship care components. During the literature review process, we identified numerous studies that addressed single needs of patients following cancer treatment. Our conversations with the KIs and our review of the literature in parallel led us to map our inclusion more closely to the construct of care coordination underlying models of survivorship care. We included studies that addressed multiple patient needs of one patient and excluded those that addressed single patient needs of one patient, regardless of whether single or multiple provider service(s) were offered. We further clarified categories of interventions as serving the following:

1. Multiple patient needs and multiple providers' services or multiple patients' needs and a single provider service. We included these studies for review.
2. Single patient's needs and multiple providers' services. (Eleven studies were excluded as “single need-multiple provider.”)34-42,46,47
3. Single patient need and single provider service. (Twenty-three studies were excluded as “single need-single provider.”)19-33,48-55

Table 1 Eligibility criteria for published studies of survivorship care

Criterion | Inclusion | Exclusion
Population | - Ages 19 or older; - Survivor of adult cancer (any cancer type); - Currently in remission with no evidence of disease; - Completed acute treatment | - Ages 18 or younger; - Adult survivor of childhood cancer; - In relapse at enrollment in a survivorship study; - Individuals with metastatic cancer
Intervention | - Two or more service(s) for survivorship care within one or more of the four core IOM survivorship care components (prevention, surveillance, intervention, coordination) intended to facilitate survivors' experience; - Formal referrals to service(s) that facilitate survivors' experiences | - Treatment with curative intent; - Studies of a single service; - Studies that provide information only on patient characteristics associated with using survivor services
Comparator | - Active comparison with other survivorship care models; - Active comparison of components of survivorship care; - Usual care; - No comparator (for case series) | - None
Outcomes | - Any patient outcomes related to the survivorship care model; - Intermediate patient health outcomes; - Morbidity; - Mortality; - Quality of life; - Satisfaction with care; - Cost and resource utilization; - Adverse events | - Outcomes attributable to the cancer treatment (except for adverse events and other long-term consequences potentially resulting from cancer treatment); - Outcomes among health care providers
Timing | - All timing related to the start of survivorship care | - None
Setting | - All care settings | - Acute inpatient care
Study design | - Systematic reviews; - Randomized controlled trials; - Nonrandomized controlled trials; - Prospective and retrospective cohort studies; - Case-control studies; - Case series | - Case reports; - Opinions; - Commentaries; - Nonsystematic reviews^a^; - Letters to the editor with no primary data
Other | - English language | - Non-English language

a Nonsystematic reviews may be used to inform our responses on GQs 1, 2, and 4.

Abbreviation: IOM = Institute of Medicine

We added this construct to our inclusion criteria by requiring two or more service(s) for survivorship care within one or more of the four core IOM survivorship care components (prevention, surveillance, intervention, and coordination) intended to facilitate survivors' experience.

### Searching for the Evidence

We systematically searched, reviewed, and analyzed the available information for GQ 3 through August 22, 2013. We then reviewed studies identified as being of potential relevance for GQ 3 and for potential relevance to the other GQs. To identify articles for this review, we conducted focused searches of PubMed, CINAHL, Cochrane Library, EMBASE, and the gray literature sources. We scanned the reference lists of systematic reviews that are pertinent but do not meet inclusion criteria to identify studies that should be considered for this review to address GQ 1, 2, or 4 as background information. We reviewed each study identified through these “hand-search” processes against the a priori inclusion and exclusion criteria described in Table 1.

### Data Abstraction and Data Management

We developed forms for the initial inclusion/exclusion process at the title/abstract and full-text review stages. Appendix B lists the sample forms used at both stages. After pilot testing and training team members, we used the forms to screen titles, abstracts, and full reviews and to gather information about study characteristics and the PICOTS (Population, Intervention, Comparator, Outcomes, Timing, and Setting) of each study.56

Two members of the research team independently reviewed all titles and abstracts identified through the published and gray literature searches against our inclusion/exclusion criteria. Reviewers categorized the studies according to relevance by GQs. All studies relevant to GQ 3 marked for possible inclusion by either reviewer underwent full-text review. For studies relevant to GQ 3 without adequate information to determine inclusion or exclusion, we retrieved the full text and then made a determination. We tracked all results of the review in an EndNote® database (Thomson Reuters, New York, NY).

We team retrieved and reviewed the full text of all studies relevant to GQ 3 included during the title/abstract review phase. Two members of the research team independently reviewed all studies relevant to GQ 3 for inclusion or exclusion on the basis of the eligibility criteria described earlier and considered the appropriateness of each study in this group for the other GQs. If both reviewers agreed that a study did not meet the eligibility criteria, the study was excluded. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consultation with a third member of the review team. We team tracked all results in an EndNote database noting the reason that each excluded full-text publication did not satisfy the eligibility criteria. Appendix C provides a comprehensive list of such studies by their exclusion reason.

We then designed evidence table data abstraction forms to gather pertinent information from each article, including characteristics of study populations, interventions, comparators, outcomes, study designs, settings, and methods. For studies that met the inclusion criteria, the reviewers abstracted relevant information from each article into summary tables using the evidence table abstraction form. All data abstractions were reviewed for completeness and accuracy by a second member of the team. Appendix D includes complete evidence tables. Appendix E provides a glossary of terms.

### Data Synthesis

To be consistent with the purpose of the Technical Brief, we did not conduct an analytic synthesis such as a meta-analysis but provides a summary of the evidence for each GQ in the following section. We considered the models used, study design, analytic methods, and the similarities and differences of included patients according to sociodemographic factors (e.g., age) and classified type of cancer detailed in the Findings.

We integrated data from the published literature with information from the gray literature and discussions with KIs. Because of the paucity of evidence, the responses to GQs 1, 2, and 4 were primarily informed by information from discussions with KIs and secondarily by published literature and gray literature or nonsystematic published reviews. When empirical evidence was not available, we focused on KI perspectives, even if these perspectives were based on individual experience and anecdote rather than empirical evidence. Responses to GQ 3 were primarily based on peer-reviewed, published literature and combined with information from the gray literature.

### Peer Review and Public Comment

The draft report was available for peer review and public comment at www.effectivehealthcare.ahrq.gov from August 9, 2013 to September 5, 2013. Five individuals or organizations offered public comment. In addition, 15 peer reviewers provided us with feedback on the draft report. We revised the report in response to these comments where appropriate.