# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Erin E. Kent, Ph.D.
  National Cancer Institute, Division of Cancer Control and Population Sciences
  Bethesda, M.D.
- Jennifer Malin, M.D., Ph.D.
  School of Medicine at UCLA
  Los Angeles, CA
- Larissa Nekhlyudov, M.D., M.P.H.
  Harvard Medical School, Department of Population Medicine
  Boston, MA
- Lee N. Newcomer, M.D., M.H.A.
  United HealthCare, Oncology, Genetics and Women's Health
  Edina, MN
- Ann H. Partridge, M.D., M.P.H.
  Harvard Medical School, Department of Medicine
  Boston, MA
- Talya Salz, Ph.D.
  Memorial Sloan-Kettering Cancer Center
  New York, NY