# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Cathy Bradley, Ph.D.^*^
  * also provided Peer Review
  Department of Healthcare Policy and Research, VCU Medical Center
  Charlottesville, VA
- Cynthia Chauhan^*^
  Patient Advocate
  Wichita, KS
- Craig Earle, M.D., M.Sc., FRCPC
  Health Services Research Program for Cancer Care Ontario and the Ontario Institute for Cancer Research
  Ontario, Canada
- Patricia Ganz, M.D.^*^
  Jonsson Comprehensive Cancer Center; UCLA
  Los Angeles, CA
- Jessie Gruman, Ph.D.
  President of the Center for Advancing Health
  Washington, DC
- Michael Kolodziej, M.D.
  Aetna
  Hartford, CT
- Jean Kutner, M.D., M.S.P.H.^*^
  University of Colorado School of Medicine, General Internal Medicine
  Denver, CO
- Mary McCabe, R.N, M.A^*^
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- Carly Parry, Ph.D., M.S.W.^*^
  National Cancer Institute, Behavioral Research Program
- James Rollins, M.D.^*^
  Centers for Medicare and Medicaid Services
  Baltimore, M.D.
- Julia Rowland, Ph.D.^*^
  National Cancer Institute, Office of Survivorship Care
  Bethesda, M.D.
- Andrew L. Salner, M.D., FACR^*^
  The Helen & Harry Gray Cancer Center
  Harford, CT
- Sherri Stewart, Ph.D.
  CDC, Division of Cancer Prevention and Control
  Atlanta, GA