# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Christine Chang, M.D., M.P.H. We extend our appreciation to our Key Informants, all of whom provided thoughtful advice and input during our research process and our Peer Reviewers for their thorough review and extensive feedback. We gratefully acknowledge the guidance our Associate Editor, Dr. Mary Butler.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI-UNC Evidence Based Practice Center. We express our gratitude to the following individuals for their contributions to this project: Lynn Whitener, Mahima Ashok, Sarah Selenich, Loraine Monroe, Jennifer Drolet, Sharon Barrell, and Carol Woodell.