# Findings

The findings from the literature search are presented in the order of the Guiding Questions (GQs) and qualitatively summarize findings from gray literature searches and interviews with Key Informants (KIs). For questions with empirical evidence or in-progress studies to inform the results, cross-cutting tables describe the state of evidence on study characteristics (e.g., number and types of study designs addressing each survivorship model or component), intervention characteristics, and types of outcomes planned or presented for each survivorship model. Figure 1 describes the number of studies at each stage of the literature search and review process that we identified for GQ 3 and the resulting studies for background (GQs 1, 2, and 4) included from this group. Appendix A lists the PubMed search terms. Appendix C lists the full exclusion reasons for exclusion codes EXC1-5. These studies describe models of survivorship care and are completed or in progress.

Figure 1 Survivorship preferred reporting items for systematic reviews and meta-analyses (PRISMA)

We searched four published literature databases (PubMed, Cochrane, EMBASE and CINAHL) and also gray literature databases and conducted hand searches. We yielded the following from each Pubmed (953), Cochrane (29), EMASE (182), CINAHL (25), Gray Literature (151) and Hand Searches (40) with a total of 1, 380 citations. Of the 1,380 articles we retrieved, 71 were duplicates giving us a total of 1,309 citations available for title and abstract review. We excluded 1,252 of the 1,309 as not relevant for Guiding Question 3 (GQ3) and had 127 citations remaining for full text review. Of the 127 citations we reviewed at the full text stage, we excluded 116 based on the exclusion categories: (EXC1: 22; EXC2: 35; EXC3: 18; EXC4: 8; EXC5: 35). We had 11 citations available for full abstraction of which we excluded two (EXC1: 1 and EXC2:1). We included 9 studies in the report.

## GQ 1 Overview of Cancer Survivorship Care

### Models of Cancer Survivorship Care

As discussed in the Background section, although the term “models” is frequently used for survivorship care programs, this term is rarely defined. Similarly, although the cancer survivorship care literature identifies or describes a wide variety of models, no commonly accepted taxonomy exists. Although these categories are neither exhaustive nor mutually exclusive, we found that authors have generally focused on the type of survivors for whom care is being provided, the setting of care, the type(s) of clinician providing care, or the purpose of the survivorship care program. Models categorized by the type of survivor receiving care are described as either disease-specific or general.57,58 McCabe and Jacobs58 describe a model specific to breast cancer as a means of meeting the needs of breast cancer survivors posttreatment. In this disease-specific model, directly after treatment ends, oncology nurses and physicians identify issues that survivors may experience (e.g., lymphedema, fatigue, psychological distress, difficulty returning to work) and provide an organized set of services to address these issues. By contrast, for a general survivorship model, nurse practitioners, oncologists, or primary care providers (PCPs) typically collaborate to provide care to survivors of all types of cancers. Both models may include a treatment summary, a care plan, or referrals for services not provided by the survivorship program.

Models categorized by setting of care generally focus on the difference between those based in “separate” survivorship clinics versus “integrative” models.57,58 Survivorship clinic models involve care for cancer survivors provided in a setting other than where the cancer treatment care was received. The setting for some survivorship clinic models may be referred to as a “consultative clinic” when a survivor is referred for a single survivorship visit. By contrast, as the name suggests, integrative models integrate survivorship care into broader oncology practice. In the integrated model, a team of health care providers may oversee survivorship care. A systematic review found that cancer survivors benefit from coordinated transition planning.59

Models that are classified based on type of clinician providing care include physician-, nurse-or nurse practitioner-led models, and models led by other types of health care providers. In addition, models may be led by a care team, with different types of providers taking the lead for different aspects of survivorship care. In section GQ 3 below, we describe and compare clinical provider-led models in more detail.

Finally, survivorship care models may be classified based on the purpose of the survivorship care program. An example is the “transition to primary care” or “transition clinic” model.57,58 As the name suggestions, the focus of this model is to transition cancer survivors away from care provided by oncologists and back to care provided by PCPs. This may involve a risk-based approach, where survivors are transitioned back to PCPs only when their risk for recurrence or late effects of cancer or cancer treatment is low. Another purpose-based classification is the multidisciplinary coordination model, characterized by clinical providers such as nurse navigators coordinating care for survivors across multiple providers.58,60 In other models, a key component is the development of a survivorship care plan (SCP) that can be provided to cancer survivors and potentially shared with their other health care providers (such as PCPs). Section GQ 3 describes examples of models in which SCPs are a key component.

The classifications for cancer survivorship care models described above are not exhaustive: other models may exist. Further, this classification is not mutually exclusive. The lack of a consistent and agreed-upon classification schema for survivorship care models results in increased challenges for comparing structures, processes, and outcomes across different models.

In addition, the literature provides little information on frequency of use of models. One study identified several models of cancer survivorship care among eight LIVESTRONG Survivorship Centers of Excellence, including disease-specific clinics, separate survivorship clinics, and integrated models.57 One systematic review listed disease-specific clinics, general survivorship clinics, consultative clinics, multidisciplinary clinics, integrated care, and transition to primary care models among the models examined.58

In response to an open-ended question about what models of survivorship care have been widely used, the four KIs commenting on this question echoed the literature: they suggested a wide variety of models exist, but little information regarding the prevalence of use is available. One KI listed three models in his organization: a group-visit model for breast cancer survivors; a model involving an individual, one-time consultation with multiple providers for breast cancer survivors; and a model involving an individual, one-time consultation with multiple providers for adult survivors of childhood cancers. Another KI described a model where care continues to be provided by an oncologist after treatment is complete and a model that involves an oncology medical home. Two other KIs indicated that no single or most widely used model of cancer survivorship care exists. In practice, they said, models of survivorship care are highly individualized: the kind of survivorship care that a survivor receives depends on the relationship between the provider and the survivor, as well as the survivor's risk associated with the disease (e.g., late toxicity).

### Components of Cancer Survivorship Care

As noted earlier, the Institute of Medicine (IOM) identified four essential components of cancer survivorship care: prevention of recurrent and new cancers, and of other late effects; surveillance for cancer spread, recurrence, or second cancers, and assessment of medical and psychosocial late effects; intervention for consequences of cancer and its treatment (e.g., medical problems such as lymphedema and sexual dysfunction; symptoms, including pain and fatigue; psychological distress experienced by cancer survivors and their caregivers; and concerns related to employment, insurance, and disability); and coordination between specialists and primary care providers to ensure that all of the survivor's health needs are met.7 In later sections of this report, we evaluate the extent to which empirical studies of survivorship care address these components.

A consensus exercise conducted by the LIVESTRONG foundation similarly identified a survivorship care plan, screening for new cancers and surveillance for recurrence, a care coordination strategy, health promotion education, and symptom management and palliative care as essential elements for which all medical settings must provide direct access or referral.61 The panel also identified other elements of care that medical settings should provide or elements for which to strive.

Several observational studies that assess the relationship between models of cancer survivorship care interventions and processes of care and/or outcomes contribute to this literature by describing components of the models.30,35,60,62,63 For example, one study assessed a model that involved a contract discharging survivors from an oncology clinic during a final visit.35 Other studies assessed interventions targeted at coordination and prevention that included SCPs, end-of-treatment consultation, followup phone calls, exercise, rehabilitation,64 counseling, and informational resources.30,62,63 KIs emphasized surveillance and intervention components as being critical to survivorship care. Specifically, one KI noted that SCPs were essential in implementing ongoing surveillance and monitoring of cancer survivors. For the intervention component, KIs also noted that interventions should address patients' physical and emotional needs, address the needs of family caregivers and prevention efforts, and be designed based on patients' risk assessment for recurrence and late effects. Some KIs also highlighted the importance of offering these components across the continuum of care and ensuring that patient empowerment and engagement is an underlying principle for each.

A survey of administrators and clinical providers from Cancer Research Network sites14 highlighted the need for survivorship care programs to address fear of recurrence, provide information about long-term effects of treatment, offer nutritional and exercise guidance, provide additional psychosocial support, and help survivors understand how to manage and coordinate their followup care.

### Nature of Current Clinical Practice for Survivors of Cancer

One observational study assessed cancer survivorship care in LIVESTRONG Survivorship Center of Excellence sites.65 Self-reports of survivors ages 18 to 39 indicated that 71 percent attended an oncology survivorship clinic at the time of the survey, 48 percent reported that they did not have a treatment summary, and 55 percent reported that they had not received an SCP. Seventy percent reported that an oncologist was the “most important” provider for test and treatment decisions; 10 percent reported receiving care in a “shared-care model” that involved both PCPs and oncologists. In another study, survivors who were diagnosed with cancer as young adults (1839) reported a lack of age-specific survivorship care, such as fertility treatment; family, couples, and sexuality counseling; and assistance with reentry into the workplace.66 Health care professionals in cancer centers and general practices in the United Kingdom reported viewing current survivorship care as reactive, focused on acute care, and incompatible with recommendations to provide proactive care.67

At least 17 guidelines for survivorship care exist.36,68-81 Guidelines vary in type of cancer (breast, prostate, lung, colorectal, and rectal) and the components of cancer survivorship care addressed. Most guidelines addressed surveillance (i.e., routine followup care and screening), but only five addressed prevention (e.g., proper nutrition and increased physical activity).69,70,72,75,82 Similarly, only nine guidelines44,70-72,74,75,78,80,81 addressed coordination. For example, one guideline72 recommended coordination between PCPs and oncologists (i.e., shared- care model). Two guidelines recommended interventions such as the expansion of evidence-based research; survivorship education for health professionals, patients, and their caregivers; and the use of SCPs.44,72

The themes that emerged from the KI interviews suggest that current clinical practice for cancer survivors reflects the variation across guidelines. First, KIs described current clinical practice as disjointed, uncoordinated, and highly varied. KIs described resources for cancer survivors including psychosocial support, assistance returning to the workforce, surveillance efforts, and prevention initiatives; however, KIs emphasized that these resources were uncoordinated and varied across cancer survivors and within cancer programs. One consequence of this lack of coordination that KIs identified was lack of clarity about roles and responsibilities among providers of cancer survivorship care. KIs suggested that a consequence of this lack of clarity about roles is the over- and underuse of surveillance testing. One KI summarized the theme of lack of coordination:

…[Current clinical practice] is still quite a hodgepodge although there is a lot of discussion about a more formal plan about how individuals should be followed once they complete treatment and it's focused on recurrence. Also, the duration of followup is also very haphazard; there is no risk-based approach for how long people need to be followed by their oncologists. The testing that is done as part of this surveillance for recurrence is also extremely variable and physician-dependent, in part because there hasn't been guidance or guidelines developed until recently. There is beginning to be some, not evidence-based, but consensus-based ways of approaching this. Many people are trying various models that fit into their own practice settings. The models are being utilized and implemented based on feasibility of staff and finances, but not any outcome data.

A second theme that emerged from KI interviews related to challenges to coordinating care for cancer survivors. Challenges included providers' lack of confidence in providing survivorship care, financial incentives that discouraged survivorship care coordination, and ineffective integration of survivorship care into cancer treatment. One KI described the influence of the Centers for Medicare and Medicaid Services' (CMS') decisions on cancer survivorship care. This KI noted that unless CMS includes a service in a benefit category, the service will not be covered. Many features of optimal cancer survivorship care are not covered currently. For example, the IOM recommended SCPs as an important feature of optimal care, but providers are not reimbursed for counseling or time spent on developing an SCP. Another KI suggested that care coordination, one of the four dimensions of survivorship care identified by the IOM, is obstructed by lack of integration into cancer treatment. The KI indicated that lack of integration of survivorship care into cancer treatment has resulted in many providers and survivors viewing survivorship care as an optional supplement to treatment, not a cohesive stage of their care.

A third theme relates to new approaches to cancer survivorship care (e.g., patient navigation, consultative models, oncology medical homes, SCPs). These approaches have emerged to address the variation and lack of coordination that is characteristic of current clinical practices for cancer survivors. Some KIs acknowledged that uptake of these approaches has been poor.

### Potential Disadvantages and Harms of Survivorship Care Models

Potential advantages and disadvantages of cancer survivorship care models compared with one another were not described in the literature or by KIs.

As described above, KIs described a lack of comprehensiveness and coordination among resources for cancer survivors. Many of the advantages of new models of cancer survivorship care address concerns related to current clinical practice. For example, some models address needs that are often not addressed in current clinical practice, such as integration back into the workforce and psychosocial issues, and they aim to prevent and detect new cancers or other chronic diseases more effectively and efficiently than current clinical practice.

KIs identified several disadvantages associated with new models of cancer survivorship care. Some disadvantages were logistical. Two KIs suggested that current financial regulations disincentivize new models. One KI suggested that oncologists have financial incentives to continue to care for cancer survivors. As noted earlier, CMS does not cover services that might be included in new models. Another logistical disadvantage of new models was their lack of integration into existing models of cancer treatment: One KI suggested that providers and survivors view survivorship care as an optional supplement to treatment, not as a cohesive stage of their care. Consequently, the KI suggested that cancer survivors may decide not to participate in new models of survivorship care.

A second category of disadvantages is related to the shift in practice patterns or clinical knowledge that may be needed for providers to accept new cancer survivorship care models. Two KIs suggested that some PCPs, who have a central role in many new models, are not confident in their ability to provide cancer survivorship care. Likewise, some oncologists question PCPs' ability to provide cancer survivorship care. Another KI suggested that providers of usual care for cancer survivors may feel threatened by new models. A third disadvantage of new models that KIs identified was their low levels of uptake, outside of early adopters.

KIs identified the following potential safety issues or harms associated with cancer survivorship care models: insufficient surveillance, intervention, and coordination; the risk of fragmentation of care with alternative approaches (e.g., models such as shared care that are intended to improve care coordination could result in care fragmentation if roles are not clearly delineated); and the risks of poorly managed latent effects due to the lack of adequate followup and coordination with current models of care.

In a survey of administrators and clinical providers from Cancer Research Network sites,14 some respondents indicated that survivorship-specific care might not add to other care already provided in oncology or primary care settings. Respondents further indicated that survivorship care programs may result in “care silos” that could undermine coordinating care for patients with multiple chronic diseases.

## GQ 2 Context in Which Cancer Survivorship Care Is Used

### Choice of and Information on Survivorship Programs

Although studies describe information needs among survivors, we found no studies that commented on whether patients and clinical care providers are informed of multiple programs and how they choose among survivorship care programs. The little information available suggests that patients are offered few choices, if any. Even treatment summaries, which can serve as a foundation for survivorship planning, are not commonly distributed. One mixed-methods study including a survey and focus groups of survivors of endometrial cancer in Canada found that only 23 percent of survivors had received some sort of treatment summary.83

Input from KIs provided context for our inability to find studies on how patients and providers access information on and choose among survivorship care programs. KIs observed that patients do not really have choices regarding survivorship programs. Their clinical providers may be unaware of services or unable or unwilling to provide services even if patients should request it. Even when they do receive services, usually the patient's insurance decides where they go. If insurance companies do not make the decision, one KI suggested that the family decides, not the patient themselves. Another KI offered the example of adult children selecting care for older patients based on their own relationship with a hospital or a provider rather than the patient's relationship.

### Sources of Variation in Survivorship Care

#### Organizational Structure and Setting

Although reviews of models of care noted settings in which these models had been implemented,58 no study described how models might vary based on organization or setting. One study reported qualitative data suggesting that in integrated health delivery settings, a distinct survivorship care program may not be needed or seen as beneficial.14 In the absence of empirical evidence, we describe anecdotal insights from KIs regarding potential variations by organization and setting.

One KI noted that “institutional flavors” of survivorship care exist. One KI suggested that variation across institutions is likely to be much greater than variation across providers and that no approach appeared to be evidence-based.

Regarding setting, one KI felt that community-based and online providers of survivorship-related resources tend to be related to wellness. The mismatch between resources and needs also emerged in KI interviews. Settings in rural areas have fewer resources but great need, and the onus for care coordination in such settings gets shifted onto the patient.

#### Provider Responsibilities and Type

One survey of concordance among patients, oncologists, and primary care providers found the greatest discrepancy between oncologists and primary care providers.84 KIs and published studies44 noted that substantial provider-to-provider variability in responsibilities exists, in part because the evidence base providing direction on what to do (as opposed to what not to do, such as ordering unnecessary scans) is weak. A survey of colorectal cancer survivors suggests an additional explanation in the variation in responsibilities and actions, namely that patient needs may differ. Survivors seen by most primary care providers were more likely to have three or more medical comorbidities than survivors seen by subspecialty physicians.85

Regarding provider type, KIs echoed concerns in the literature about the impending shortage in the oncology workforce to address the needs of growing numbers of survivors,3,15 although, as one KI noted, community oncologists like to continue to see survivors because “it keeps them sane,” to balance their case load of severely ill patients with a poor prognosis with cancer survivors. A qualitative study supports this perspective, noting that oncologist “feel protective of and possessive of some patients”.86, ^p. S462^

The pending workforce shortage in oncology points to the need for nurse practitioners and physician assistants. KIs noted that patients view nurse practitioners as extensions of the oncologist and trust them. Regarding patient preferences for provider roles in survivorship, a survey of adult cancer survivors identified from hospital databases and clinic lists at a regional cancer center in Sheffield, United Kingdom, suggested that regardless of cancer type, cancer survivors preferred consultant-led (i.e., oncologist or other specialist) care to nurse-led, telephone, or general practitioner-led care.87 A study of breast cancer survivors in the United found similar results when patients were asked about the effect of various followup visits on cancer-related worrying: visits with oncologist significantly decreased the odds of worrying compared with visits with primary care providers.88

A possible explanation for the stated preferences for consultants might be patients' preference for continuity of care and the value that survivors place on their relationship with specialists who treated their cancer.89 Although survivors were receptive to the idea of greater involvement of their general practitioner in followup care in shared care with an oncologist89 as well as nurse-led care,89,90 they noted concerns about lack of specialized training. Additionally, they expressed some concerns about reluctance on the part of primary care practitioners to take on survivorship care. This view is confirmed by a qualitative study of primary care practitioners themselves who note concerns with lack of access to information and poor communication with oncologists, the complexity of needs of survivors, and medical-legal implications of providing oncology followup.86

A survey of primary care providers in Canada found willingness on the part of the participants to take on exclusive care of survivors but noted the need for a patient-specific letter from the specialist, printed guidelines, expedited routes of re-referral, and expedited access to investigations for suspected recurrence.91 A structured review of followup of breast cancer patients found evidence that general practitioner-led care is as effective as specialist care, but this review was evaluating empirical evidence of patients attending a routine followup service after treatment rather than broader survivorship care services.92 The review was based on studies from numerous countries including the United States, but the extent to which these findings vary by geographic setting is unclear. Likewise, the implications of these findings in a setting with predicted shortages in PCPs are also unclear.

Some KIs suggested that a shared-care model offers the greatest promise in common instances where community PCPs feel ill equipped to assume total care for cancer survivors. They noted that expecting PCPs to remember recommendations for all types of cancers is not realistic. Other KIs struck a note of caution regarding the shared-care model, noting the risk of fragmentation of care, lack of clarity about roles and responsibilities, and unnecessary tests.

A study of trends in followup and preventive care for colorectal cancer survivors found increasing numbers of visits to all physician types; these trends were statistically significant for oncology specialists and other physicians, but not primary care providers.93 We did not see evidence that the increase in physician visits was accompanied by a shift in visits from specialists to primary care practitioners: one study of a convenience sample of young adult cancer survivors, recruited through the LIVESTRONG Survivorship Centers of Excellence Network, suggests modest anticipated changes in provider types. The majority (70 percent) of the convenience sample considered their oncologist as the doctor in charge of the most important treatment or test decisions. This sample included patients with very variable median time since diagnosis from 7 to 328 months. As many as 69 percent anticipated they would continue to rely on their oncologist for the next 6 months. Only 10 percent relied on a shared-care model as the approach addressing the most important treatment or test decisions, and the proportion expecting to continue to rely on shared care in the upcoming 6 months declined to 5 percent. The proportion relying on a PCP at the time of the survey was 4 percent; 10 percent anticipated relying on PCPs in the upcoming 6 months. Multivariate analysis suggested that the model of care was not a significant predictor of the level of confidence young adults had in managing survivorship care.65

#### Payment Considerations

A fundamental constraint to financial feasibility of offering survivorship care is the cost of preparing treatment summaries and SCPs.57 In addition to the issue of reimbursement for SCPs, coverage for clinical services can be a problem.57 Several KIs, including clinical providers and patient advocates, also noted the difficulty, from the provider's perspective, in providing a financially sustainable model of care. In some cases, the reimbursement structure is such that oncologists may express interest in providing survivorship care, but they “always say they don't get paid for [SCPs] and it takes a lot of time.” Therefore, to provide proper survivorship care or to transition the patient is difficult financially. One study also reported that the availability of resources, particularly in specialized clinics, as well as patient financial concerns and insurance reimbursement, were challenges to providing survivorship care.14

KI interviews also suggested some differences in the perception of the willingness of insurance companies to pay for such care. Some KIs suggested that most insurance (with the exclusion of high-deductible insurance) would typically cover such services, but one clinical provider suggested that insurers were unlikely “to step up because there's nothing in it for them. There's no money involved.”

Nonetheless, KIs were in broad agreement that survivorship care services were not expensive. Several KIs focused on the enormous attention to and costs of treatment relative to survivorship care, with one KI asking, “Why do we dump all this money into treatment if we let patients fade out at end?”

#### Patient Characteristics Such as Age, Race/Ethnicity, and Cancer Type, Stage of Disease

Patient characteristics may predict interest in and uptake of survivorship care in addition to patient needs for survivorship care. Available literature and KIs suggest that the type of cancer may influence interest in and variation in survivorship care models. Following the launch of an Internet-based tool for the creation of SCPs, an evaluation of users found that breast cancer represented the most commonly reported primary cancer diagnosis (over 45 percent), followed by hematologic, gastrointestinal, gynecologic, and genitourinary malignancies.94,95 Likewise, the type of cancer may influence interest in specific services. In focus groups of self-selected participants, the breast cancer focus group in particular expressed a need for more spiritual support during active treatment and followup care.90

KIs also identified age, race, socioeconomic status, and insurance status as key variables that might influence survivorship care needs. In a convenience sample of young adult cancer survivors recruited through the LIVESTRONG Survivorship Centers of Excellence Network, multivariate analysis showed that minority racial status and lacking a followup SCP were associated with greater odds of low confidence in managing survivorship care.65 A survey of cancer survivors identified through the Pennsylvania Cancer Registry found that age, number of comorbidities, income, stage of disease, and the interaction between age and number of comorbidities predicted the level of unmet need.96

### Associated Supportive Care Resources Needed in Survivorship Care Programs

The literature on supportive care needs varies by the type of cancer survivors (younger adult,87 cancer survivors with preexisting cardiopulmonary disease,97 gynecological cancers,98 breast cancer survivors,89,99,100 and patients from the Pennsylvania Cancer Registry96). These studies include a range of data sources, including registry-based studies;11,96,101 a survey of cancer survivors identified from hospital databases and clinic lists at a regional cancer center in Sheffield, United Kingdom;87 a secondary analysis of the LIVESTRONG survey of self-selected respondents from partner organizations and cancer coalitions of the Lance Armstrong Foundation;97 several qualitative studies with cancer survivors in Australia,89 New Zealand,98 and the United States;100,102 and a literature review of qualitative and quantitative studies of patient perspectives.99

Registry-based studies consistently show that survivors have significant unmet information needs years after diagnosis. One registry study found that nearly two-thirds of cancer survivors in Pennsylvania had at least one unmet psychosocial need as long as 3.0 to 4.5 years from diagnosis, and nearly half had over three unmet needs. The greatest need was expressed for emotional needs, followed by physical needs.96 Similarly, the majority of endometrial cancer survivors in a Dutch registry-based study reported no information on psychological assistance, rehabilitation, additional help, coping with cancer at home, and expected results of treatment on social and sexual life. These patients expressed interest for more information on possible cancer causes; prevention and risk of recurrence; possible side-effects of treatment, including effects of treatment on their sexual life; and psychological support.11 Data from two cancer registers in California also found a wide range of health information need for survivors 4-14 years after diagnosis, particularly for younger and nonwhite patients.101

The LIVESTRONG survey suggested that physical needs are more likely to be met than either emotional (over 60 percent with unmet needs) or practical needs (over 70 percent with unmet needs).97 The survey found that “fifty-four percent of respondents indicated they would have liked more followup support after completing treatment” and that “approximately one third left their doctor's office with unanswered questions, and 25 percent reported that the health care team did not seem open to discussing their questions or problems.”97, ^p. 1353-1354^ The need for additional information is echoed by the qualitative studies that highlighted the need for more discussion of or information on psychological well-being, postoperative expectations and the reality of functional limitations, and late physical effects.66,89,90,98-100,102

KIs offered perspectives on the logistics of offering supportive care services to patients. One KI noted that because the specialist may not have information about counseling services, exercise, and physical therapy, the survivorship clinic is the only mechanism through which emotional needs, substance abuse, and other diagnoses are discovered. She noted that many supportive care services already exist and that there is “no reason to recreate the wheel and bring it in house.” Care providers can just refer patients out as needed. All settings need to be repurposed for survivorship care, but one “does not need to own the resource to use it.”

Another KI noted that planning for supportive care resources needs to start during therapy. The KI noted that patients are focused on their health status during treatment. She noted the importance of working with patients from the beginning so that therapy is more compatible with patients' schedules. Patients need to get additional information that will assist them with their work life once their treatment is over. Patients need to know what their rights are, what kinds of accommodations they can get, what information to reveal when looking for a new job, and options for health insurance if they have quit working.

### Application of Risk Stratification to Cancer Survivor Models

We did not find studies describing how risk stratification had been or might be applied to cancer survivorship models (although guidelines for specific conditions may account for underlying risk), although studies noted the importance of tailoring SCPs for the individual.83,90 KIs were in agreement, however, that SCPs need to be tailored for risk. As one KI pointed out, active treatment requires an assessment of risk, so survivorship care should as well. KIs also noted that evidence-based guidelines for survivorship do not account currently for risk stratification and that physicians do not really understand risk of new cancers and risk of recurrence.

Regarding specific sources of risk, comorbidities may influence the risk of poor outcomes following cancer treatment.103 KIs noted that providers may use age as a proxy for comorbidities in risk stratification. Life course also matters: another KI pointed to research showing that a longer chemotherapy course in conjunction with a more cognitively demanding job results in poorer quality of life, worse self-reported health status, and delayed return to work for survivors.

When asked about incorporating patient characteristics into an assessment of risk that might influence the selection of a survivorship care model, one KI offered a three-tiered approach to managing a heterogeneous survivor population. The KI suggested that patients can be characterized as (1) low-risk patients who can be transitioned immediately to a PCP because they do not have much need for long-term oncological care, (2) medium-risk patients who can be transitioned over a 2- to 5-year period to the PCP, and (3) high-risk patients who require ongoing care by both their oncologist and PCPs for life (e.g., transplant patients). Patient advocates also supported the idea of a continuum of need based on patient characteristics and the need for a matching process between patient characteristics and models of care.

### Resources Needed To Share Information Among Health Care Providers and With Patients

A mixed-methods project that combined archival data with KI interviews of the leaders of the LIVESTRONG Centers of Excellence identified some frustration with information systems that were designed to support clinical care and billing but were not designed to extract information to develop treatment summaries and SCPs.57 Communication also emerged as a key issue for both clinical providers and patient advocates among our KIs, but their perspectives on the resources needed to share information, particularly the role of patient navigators, differed substantially. Clinical providers noted their struggles communicating with all members of the team and with patients. Regarding communicating with other clinical providers, one KI noted that having a shared electronic medical record would ease communication among providers and organizations (as was noted in a study describing medical records as critical14), but the KI was unaware of any resources for provider communication. The KI noted that many hospitals do not have a single electronic health system, and the multiple systems within a hospital often do not communicate. Even when communication occurs (for instance, when an oncology nurse faxes information following a survivorship visit to the PCP's office), it is unclear how well that information is absorbed by the PCP. SCPs need to be kept cogent, short, and in a format that is likely to be read by all members of the care team, including the PCP.

As for communicating with patients, the KI noted that a study of a single survivorship visit found that although patients liked having the visit, they did not retain information presented during the visit, suggesting the need for reinforcement of education provided at the survivorship visit through other methods (e.g., mail, newsletter, additional visits, and telephone followup). Providers pointed to patient navigators (either virtual or in person) as a potentially promising avenue to explore in future research. A survey of concordance in expectations between patients, oncologists, and primary care providers found that better concordance between patients and oncologists was associated with improved followup care, but only if a discussion about cancer followup had occurred.84

Patient advocates noted the same concerns as clinical providers did with the failure of electronic systems to communicate with one another. Not only are patients failing to receive care coordination in which providers communicate with one another, but they are also subject to treatment decisions from various providers who are working from different sources of information. Patient advocates noted that these gaps in communication place a tremendous burden on already stressed and ill patients to serve as “sole arbiters” of which doctor received which piece of information. Although one patient advocate noted the potential role of an ombudsman to take responsibility for patient coordination, both were cautious about the increasing emphasis on patient navigators. The implementation of patient navigation includes a lot of uncertainties regarding “who does what, how it is funded, [and] how people are held accountable.”

These insights suggest that beyond resources needed to share information, processes such as teamwork and team functioning and workforce training on teamwork also matter.

### Considerations for Evaluating Appropriate Resource Utilization, Cost, Quality of Care, and Outcomes for Survivorship Programs

We did not find studies that listed considerations for evaluating survivorship programs. One KI noted these considerations are much bigger than the field of oncology. At the moment, no avenue exists to hold anyone accountable for the long-term survivorship care of people with cancer. A larger alignment of incentives, payment reform, and accountable care organizations might make a difference. Regarding specific evaluation considerations, KIs suggested focusing on level of patient satisfaction with their survivorship care, knowledge about their disease (including risks, recommended surveillance, and healthy behaviors), and subsequent patient behavior following education.

One KI with a payer perspective noted that coverage for care coordination is possible if care coordination demonstrates (i.e., with evidence) that it can improve patient care or provide clinically meaningful benefit to the patient. He noted that quality of life is a “soft” outcome in coverage determination, so quality of life alone may not be sufficient. Other meaningful measures of the consequences of services include decreased resource utilization rates (e.g., decreased hospitalization, decreased emergency room visits, or even decreases in certain medications that are expensive).

### Uptake and Duration of Survivorship Care

We found no studies describing the uptake and duration of survivorship care on the whole. For studies with empirical evidence, the duration of the intervention ranged from 7 weeks62 to 4.2 years.104 A structured review of followup of breast cancer patients found some discrepancies in the literature, with guidelines and data suggesting that the frequency and length of the followup service should be tailored to meet the needs of individual patients on the one hand and one study finding evidence of overutilization of followup visits on the other.92 In addition, we noted that based on a systematic review of 38 articles addressing followup care for breast cancer survivors, neither quality of life nor overall survival was affected by the frequency, duration, or type of followup care received.92 KIs generally did not comment on or were unaware of generalizable information on the uptake and duration of survivorship care.

### Training and Staffing Needed for Survivorship Care

Studies described earlier identified concerns with the level of training or specialized knowledge held by PCPs and nurses. Existing literature suggests that development of training resources for adult survivorship care is at an early stage of development. The American Society of Clinical Oncology (ASCO) position statement drew particular attention to the importance of planning followup care and coordination of care in a shared-care model. The ASCO position statement also noted the importance of collaborating with nonspecialty boards to determine the specific knowledge needed for proof of proficiency for certification.44 For primary care physicians, a position paper suggested the need for an internal medicine credential in cancer survivorship care.105 KIs were in agreement that no survivor-specific training or certifications exist beyond the underlying certification for each discipline. Although KIs concurred on the need for continuing medical education as a way to train oncologists who are already practicing, they offered different perspectives on how to train the workforce. One KI focused on a train-the-trainer model as a more promising approach than training an entire health care workforce on survivorship care through a specialized training track, but another KI noted the importance of better integration of survivorship needs in clinical provider curricula.

KIs agreed that targeting nurse practitioners in survivorship-related specific training or certification would be particularly helpful and that nurse practitioners had the right training and skills to address survivorship issues with patients.

## GQ 3 Current Evidence on Cancer Survivorship Care

Based on the inclusion criteria described above, we identified nine studies that presented information on models of cancer survivorship care. As discussed in section GQ 1 (above), many taxonomies for survivorship care models are based on the health care provider leading the intervention (e.g., oncologist-led, PCP-led, nurse-led, or shared care), the site of care (e.g., academic center-based versus community-based), or the main purpose of the model (e.g., transition to primary care). In reviewing these nine identified studies, we identified four model categories based on the main foci of these studies: physician-led models, nurse-led models, models in which SCPs are a key component, and a model comparing group versus individual counseling. We discuss these studies in the sections below using these four model categories.

Substantial heterogeneity existed among these studies, including the specific survivorship care models, the type of cancer(s) for which survivors had been treated, and the duration and intensity of followup. Three studies compared differences in survivorship care programs led by physicians.104,106,107 All three of these studies involved comparisons between two or more survivorship protocols. Two of the identified studies examined nurse-led survivorship care models.108,109 Three studies featured SCPs as a key component.62,110,111 Although all three involved health care personnel (e.g., all included nurse-led components), a key component of these models is developing and disseminating a tailored SCP. We have therefore included these models in a separate category. In each of these three studies, the SCP was presented to the survivor during a nurse- or nurse practitioner–led visit and was shared with the survivor's PCP. Finally, Naumann et al. examined individual versus group-based counseling and exercise training for cancer survivors.63

We present details regarding the design and intervention characteristics of these studies in Tables 2 and 3, respectively. We also present information on dissemination and communications components of these studies in Table 4. The outcomes for each of these studies are available in Table 5.

Table 2 Design characteristics of studies of survivorship care models

Type of Survivorship Intervention | Author and Year | Sample Size | Comparison Among Survivors Receiving Different Types of Care (e.g., Comparison With Usual Care, by Provider Types, Single vs. Multiple Providers, Resource Utilization Frequency) | Survivors Randomized to Study Arm | Survivors With Multiple Cancer Types Included | Survivors Across Multiple Stages of Disease Included
Physician-Led Survivorship Care Models | Cannon et al., 2010^106^ | 314 | X | – | X | NA
Physician-Led Survivorship Care Models | Kokko et al., 2005^104^ | 472 | X | X | – | X
Physician-Led Survivorship Care Models | Wattchow et al., 2006^107^ | 203 | X | X | – | X
Nurse-Led Survivorship Care Models | Gates et al,, 2012^109^ | 60 | – | – | – | NA
Nurse-Led Survivorship Care Models | Knowles et al., 2007^108^ | 60 | – | – | – | X
Survivorship Care Models in Which SCP Development Is a Key Component | Curcio et al., 2011^110^ | 30 | – | – | X | X
Survivorship Care Models in Which SCP Development Is a Key Component | Grunfeld et al., 2011^111^ | 968 | X | X | – | X
Survivorship Care Models in Which SCP Development Is a Key Component | Jefford et al., 2011^62^ | 10 | – | – | – | X
Survivorship Care Models Comparing Group vs. Individual Counseling | Naumann et al., 2012^63^ | 40 | X | – | – | X

Abbreviations: NA = not applicable (for studies of survivors of hematologic malignancies); SCP = survivorship care plan.

Note: X indicates study reported the characteristic; – indicates that the study either did not have the characteristic or did not report it.

Table 3 Intervention characteristics of studies of survivorship care models

Type of Survivorship Intervention | Author and Year | Setting | Transition of Care Explicitly Incorporated Into Intervention | Economic Considerations Described | Survivorship Intervention Starts <1 Year After Completing Treatment | Survivorship Intervention Duration of <1 Year | Model Includes Care Provided by Telephone
Physician-Led Survivorship Care Models | Cannon et al., 2010^106^ | Teaching hospital system | – | – | – | X | –
Physician-Led Survivorship Care Models | Kokko et al., 2005^104^ | Hospital department of oncology | – | X | – | – | X
Physician-Led Survivorship Care Models | Wattchow et al., 2006^107^ | Multiple hospitals | – | – | X | – | –
Nurse-Led Survivorship Care Models | Gates et al,, 2012^109^ | Public teaching cancer hospital | – | – | – | X | X
Nurse-Led Survivorship Care Models | Knowles et al., 2007^108^ | Hospital surgical department outpatient clinic | – | X | X | – | X
Survivorship Care Models in Which SCP Development Is a Key Component | Curcio et al., 2011^110^ | Community cancer center | X | X | – | X | X
Survivorship Care Models in Which SCP Development Is a Key Component | Grunfeld et al., 2011^111^ | Tertiary care cancer centers and physician offices | X | – | X | – | –
Survivorship Care Models in Which SCP Development Is a Key Component | Jefford et al., 2011^62^ | Teaching hospital | X | – | X | X | X
Survivorship Care Models Comparing Group vs. Individual Counseling | Naumann et al., 2012^63^ | NR | – | – | X | X | –

Abbreviations: NR = not reported; SCP = survivorship care plan; vs. = versus.

Note: X indicates study reported the characteristic; – indicates that the study either did not have the characteristic or did not report it.

Table 4 Information dissemination and communications in survivorship care models studies

Type of Survivorship Intervention | Author and Year | Tailored Materials Prepared for Survivors | Materials Shared With Other Health Care Providers (Not Directly Part of the Survivorship Care Model) | Direct Care Coordination/Communications With Other Health Care Providers (Not Directly Part of the Survivorship Care Model)
Physician-Led Survivorship Care Models | Cannon et al., 2010^106^ | – | – | –
Physician-Led Survivorship Care Models | Kokko et al., 2005^104^ | – | – | –
Physician-Led Survivorship Care Models | Wattchow et al., 2006^107^ | – | – | –
Nurse-Led Survivorship Care Models | Gates et al., 2012^109^ | X | X | –
Nurse-Led Survivorship Care Models | Knowles et al., 2007^108^ | – | – | –
Survivorship Care Models in Which SCP Development Is a Key Component | Curcio et al., 2011^110^ | X | X | –
Survivorship Care Models in Which SCP Development Is a Key Component | Grunfeld et al., 2011^111^ | X | X | –
Survivorship Care Models in Which SCP Development Is a Key Component | Jefford et al., 2011^62^ | X | X | –
Survivorship Care Models Comparing Group vs. Individual Counseling | Naumann et al., 2012^63^ | – | – | –

Abbreviations: SCP = survivorship care plan; vs. = versus.

Note: X indicates study reported the characteristic; – indicates that the study either did not have the characteristic or did not report it.

Table 5 Outcomes of cancer survivorship models studied

Type of Survivorship Intervention | Author and Year | Quality of Life | Depression | Anxiety/Distress | Well-being | Satisfaction | Resource Utilization | Adherence to Planned Followup | Disease free Period | Overall Survival | Recurrence | Perceptions of Health | Engagement in Health-Promoting Activities | Cancer Survivors' Knowledge | Coordination/Continuity of Care | Unmet Needs
Physician-Led Survivorship Care Models | Cannon et al., 2010^106^ | X | – | – | – | X | X | – | – | – | – | – | – | – | – | –
Physician-Led Survivorship Care Models | Kokko et al., 2005^104^ | X | – | – | – | – | X | – | X | X | X | – | – | – | – | –
Physician-Led Survivorship Care Models | Wattchow et al., 2006^107^ | X | X | X | – | X | X | – | – | X | X | – | – | – | – | –
Nurse-Led Survivorship Care Models | Gates et al,, 2012^109^ | – | – | – | – | – | – | – | – | – | – | X | X | – | – | –
Nurse-Led Survivorship Care Models | Knowles et al., 2007^108^ | X | | – | | X | – | X | – | – | X | – | – | – | – | –
Survivorship Care Models in Which SCP Development Is a Key Component | Curcio et al., 2011^110^ | – | | X | – | X | – | X | – | – | – | – | – | X | – | –
Survivorship Care Models in Which SCP Development Is a Key Component | Grunfeld et al., 2011^111^ | X | | X | – | X | – | – | – | – | X | – | – | – | X | –
Survivorship Care Models in Which SCP Development Is a Key Component | Jefford et al., 2011^62^ | X | | X | – | X | – | – | – | – | – | – | – | – | – | X
Survivorship Care Models Comparing Group vs. Individual Counseling | Naumann et al., 2012^63^ | X | – | | X | – | – | – | – | – | – | – | – | – | – | –

Abbreviations: SCP = survivorship care plan; vs. = versus.

Note: X indicates study reported the characteristic; – indicates that the study either did not have the characteristic or did not report it.

### Studies of Survivorship Care Models

#### Design Characteristics

Over half of the included studies (n=5) had a sample size of fewer than 100 patients; the sample sizes ranged from 10 to 968 (Table 2). Six of the studies were comparative in nature, but only three of these six randomized the survivors to a study arm (no studies involved randomization at the practice level). Other comparative studies involved following cancer survivors who had chosen different types of care programs; these studies correspond more to a “real-world” approach for survivorship care, but this approach increases the likelihood of substantial differences (and resulting bias) among participants in different types of survivorship care. All of the physician-led survivorship model studies were comparative. By contrast, fewer of the other studies included comparisons. Similarly, most of the physician-led studies involved randomizing survivors to treatment arms whereas few of the other studies included randomization. Two of the nine studies106,110 included survivors with multiple cancer types: one included survivors with different types of hematological cancers106 and the other included survivors of breast, gastrointestinal, lung, and hematologic cancers.110 All of the studies except the two involving survivors of hematologic malignancies (where stage is not applicable) included survivors who had been diagnosed at multiple stages of disease, although all studies excluded individuals with metastatic disease.

Both the Wattchow et al.107 and Cannon et al.106 studies appear to have examined “usual care” for survivors in that there is no specific intervention to modify standard practice patterns. The Kokko et al. study104 involved what may have been more differences from usual care, in that survivors were randomized to different followup visit intervals and protocols for diagnostic testing (routinely performed versus performed only for clinical reasons).

#### Intervention Characteristics

The studies' settings comprised cancer centers (both academic and community) and hospitals (Table 3). One study was based in a community cancer center.110 The three studies in which SCPs were a key component incorporated transition of care explicitly as a facet of the survivorship care model only.62,110,111 Three of the studies, from three different survivorship model categories, included analysis of economic considerations.104,108,110

Five of the studies involved survivorship care interventions starting within 1 year following completion of active treatment. The Gates et al. study,109 by contrast, required that enrollees had completed 5 years following active treatment. Five studies (not the same five with interventions starting within 1 year) included followup of survivors for less than 1 year. By contrast, the Knowles et al.108 study followed survivors for up to 36 months (for colon cancer survivors) or 48 months (for rectal cancer survivors). Five of the models incorporated telephone contacts as a component of the planned survivorship care.

#### Information Dissemination and Communications

Four of the studies62,109-111 involved developing tailored materials for cancer survivors (Table 4). Of these, three were studies in which SCPs were a key component; by definition these interventions include tailored materials for survivors. All four of these studies also shared these individually tailored materials with the survivor's other health care providers. Although other studies examined may have shared materials with survivors and their health care providers, this was not explicitly stated. Interestingly, none of these studies involved direct communications or care coordination between the clinical providers leading the survivorship care models and other providers involved in the survivor's medical care.

#### Outcomes

Quality of life and satisfaction were the most commonly reported outcomes across the studies (Table 5). All but two studies109,110 included a quality of life outcome; interestingly, both of these studies included developing tailored materials for survivors. The three physician-led models were the only studies to include assessment of resource utilization, although only one of these three104 explicitly assessed costs. Four studies explicitly included information on disease recurrence, although all models likely tracked recurrence for the period of survivor followup. Only two studies included assessment of overall survival, possibly reflecting the short duration of followup for many of the models.

All three of the models in which SCPs were a key component examined both distress/anxiety and patient (i.e., survivor) satisfaction. However, in general, studies in the same survivorship care model categories did not assess the same types of outcomes. For example, the two nurse-led interventions did not have any outcomes in common. Depression and well-being were each explicitly assessed in only one study. However, these outcomes may have been incorporated in quality-of-life assessments included in other studies. Other outcomes present in only a single study included perceptions of health, engagement in health-promoting activities, cancer survivor's knowledge, care coordination/continuity, and unmet needs.

Beyond the studies addressing resource utilization or costs, all outcomes in the identified studies were at the patient level. There were no other provider- or systems-level outcomes presented.

#### IOM Components Addressed

Table 6 summarizes the IOM survivorship care components addressed by each reviewed model. The model examined by Wattchow et al. addressed two of the four IOM-recommended components of survivorship care: surveillance (for recurrence of colon cancer or development of new cancers) and intervention (to address symptoms potentially associated with cancer or cancer treatment).107 We were unable to determine which IOM survivorship care components were addressed as part of the Cannon et al. study, although survivors being followed by multiple providers may have had coordination addressed. Similarly, although the Kokko et al. study explicitly addressed the IOM survivorship care component of surveillance, we were unable to determine if any other components were addressed.104 The model reported by Knowles et al. appears to address only two of the IOM cancer survivorship model components (surveillance and intervention). The model in the Gates et al. study, by contrast, appears to address all four components.109 In particular, the nurse-led program described by Gates et al. explicitly included components that did not appear to be present in the Knowles et al. model, specifically, educating survivors regarding adoption of healthy lifestyle behaviors (prevention component) and sharing the SCP with the survivor's PCP (coordination component).

Table 6 IOM survivorship care components

Type of Model | Author and Year | Prevention | Surveillance | Intervention | Coordination
Physician-Led Survivorship Care Models | Cannon et al., 2010^106^ | – | – | – | –
Physician-Led Survivorship Care Models | Kokko et al., 2005^104^ | – | X | – | –
Physician-Led Survivorship Care Models | Wattchow et al., 2006^107^ | – | X | X | –
Nurse-Led Survivorship Care Models | Gates et al,, 2012^109^ | X | X | X | X
Nurse-Led Survivorship Care Models | Knowles et al., 2007^108^ | – | X | X | –
Survivorship Care Models in Which SCP Development Is a Key Component | Curcio et al., 2011^110^ | X | X | X | X
Survivorship Care Models in Which SCP Development Is a Key Component | Grunfeld et al., 2011^111^ | – | X | X | X
Survivorship Care Models in Which SCP Development Is a Key Component | Jefford et al., 2011^62^ | X | X | X | X
Survivorship Care Models Comparing Group vs. Individual Counseling | Naumann et al., 2012^63^ | X | – | X | –

Abbreviations: IOM = Institute of Medicine; SCP = survivorship care plan; vs. = versus.

Note: X indicates study reported the characteristic; – indicates that the study either did not have the characteristic or did not report it.

The models reported by Curcio et al. and by Jefford et al. appear to address all four of the IOM survivorship care components.62,110 The model examined by Grunfeld et al. appears to address the surveillance, intervention, and coordination components; it is not clear whether it addressed the prevention component.111

The group versus individual counseling model addressed the prevention and intervention IOM survivorship care components.

### Conclusions From the Literature Review

Our review of the studies identified by this systematic review of the literature for the Technical Brief indicates a number of important findings regarding the model-of-survivorship care literature.

First, we reviewed a large body of literature, but we were only able to identify nine published studies that met our definition of survivorship models (i.e., programs for cancer survivors that addressed two or more different health care needs). Much of the available literature described only a single service for cancer survivors and thus did not correspond to a holistic and coordinated model or meet our inclusion criteria. However, less than a decade has passed since the dissemination of the IOM report that called for the recognition of the distinct phase of survivorship care (recommendation 1) and for CMS, the National Cancer Institute (NCI), AHRQ, and others to support demonstration programs to test models of care (recommendation 5). It is therefore not surprising that we identified few studies meeting the definition of survivorship models.

As discussed above, the nine identified studies are heterogeneous with respect to the type of survivorship care model, characteristics of the survivors participating, and intensity and duration of the interventions and outcomes measured. For example, time since completion of active treatment varied from essentially immediately following completion (Kokko et al.104) to a median of 12 years (Gates et al.109). This heterogeneity provides challenges in identifying trends or making comparisons across the different models. However, the heterogeneity in studies may reflect the heterogeneity of the cancer care delivery system, which involves multiple health care providers and often multiple practice locations. Thus, the models used by clinical providers that have become early adopters in the implementation of survivorship care may reflect the heterogeneous institutional and community resources that are available for survivors. At this point, the described models serve as “stand-alone” examples, with only limited ability to assess comparative effectiveness or draw generalizable conclusions for the overall survivor population.

Outcomes assessed across the identified studies were also heterogeneous. Many of the studies assessed health-related quality of life, but differing instruments were used. Some studies assessed knowledge, satisfaction, adherence to recommended followup, or resource utilization, but this was also variable. The lack of a standard or minimal set of metrics to evaluate the impacts of survivorship care models creates substantial barriers to making comparisons among alternative models. The models varied in terms of the IOM survivorship care components addressed. Most models addressed surveillance (for recurrent or new cancers) and intervention (for symptoms or conditions resulting from the cancer or cancer treatment). Fewer models addressed prevention (i.e., encouragement to adopt healthy lifestyle behaviors) or care coordination. Further, studies that did incorporate care coordination largely involved only sharing information (such as an SCP) with the survivor's PCP. Models may need to explore more detailed approaches to care coordination, including the resources needed to exchange information among diverse groups of health care providers, survivors, and caregivers.

In general, nurse-led models and models in which developing SCPs is a key component appeared to address more IOM components. Overall, it is not surprising that the models identified for this study did not address (i.e., include interventions focused on) all IOM components. As reported by Salz et al.,112 only 43 percent of NCI-designated cancer centers present SCPs to their breast or colorectal cancer survivors, and none of these address all components recommended by the IOM.

Within each study, participant characteristics were also heterogeneous; for example, several studies involved individuals diagnosed with stage I through stage III disease. None of the studies described specific risk stratification protocols, where survivors who had more extensive disease at diagnosis or who received more intensive therapy were provided with different types of information or different supports than were those with less extensive disease or treatment. Several of the review models included individualized components (e.g., SCPs), which may have been tailored to reflect individual risk levels, but this was not explicitly stated. Completeness of information reporting in these nine studies also varied and, for certain types of study data, information was largely absent. For example, none of the studies reported any adverse events or unintended consequences of the survivorship care model, such as overuse of services or duplicate testing. It may be that no such unintended consequences occur; however, it would be useful for researchers to explore this issue and comment on such negative results if that is the case. This may also be useful as an outcome measure for survivorship care reflecting effectiveness of communication and coordination of care.

Other than the report by Curcio et al,110 the reviewed studies either included few nonwhite survivors or did not report the proportion of nonwhite survivors participating. Although some studies took place in countries with low proportions of nonwhite individuals (e.g., Finland), the low level of involvement of nonwhite survivors parallels low participation rates observed in therapeutic cancer clinical trials. African-American and Hispanic individuals are significantly less likely to participate in cancer clinical trials than white individuals.113 Patient-level barriers to participating in studies of survivorship care, such as sociocultural factors and distrust of the medical establishment; trial design factors such as eligibility criteria; and provider-level factors have been reported to limit participation by African Americans in therapeutic cancer clinical trials.114 Many barriers to participating in studies of survivorship care may also limit receipt of survivorship care among disparate populations. Developers of cancer survivorship care models should consider potential barriers to participation (in both studies and care programs) by racial/ethnic minorities and other underserved populations and provide information on enrollment by these disparate groups.

Several of the identified studies do not include a “usual care” arm. To evaluate the effectiveness of a survivorship care model and compare effectiveness among differing models, a common “baseline” of standard survivorship care is needed. The absence of comparisons with standard survivorship care practices (i.e., in the absence of a protocol-specified intervention) limits the ability to assess whether a more integrated or comprehensive model of survivorship care would differ from a less integrated or comprehensive model in clinical outcomes or efficiency of care delivery for cancer survivors. Similarly, the absence of comparison to usual care prevents assessment of the potential harms that may result from survivorship care models. Additional research is needed to explore whether (and how) various models of survivorship care are likely to improve outcomes for cancer survivors compared with current survivorship care practices.

A recent Cochrane collaboration review by Scott et al.115 identified published studies that examined the effectiveness of “multidimensional rehabilitation programmes” for cancer survivors. The differences between this review and the present Technical Brief illustrate important challenges in examining models of survivorship care. Scott et al. identified 12 published randomized controlled trials that included both physical and psychosocial interventions for adult cancer survivors. However, these 12 studies did not overlap with the 9 studies identified in this Technical Brief. Furthermore, these 12 studies were not identified in the literature searches performed for the Technical Brief; separate and largely distinct search terms were used to identify studies for review. The search strategy used by Scott et al. started with publications involving neoplasms, and then searched for studies that included a range of intervention and health care service types (e.g., self-help groups, psychotherapy, social work, dietary services, physical therapy). In contrast, our literature search started with cancer survivors and then examined studies focused on delivery of health care, aftercare, models of care, and related topics. This approach resulted in a group of studies that were more focused on the specific aims for this Technical Brief.

Had we identified these 12 studies as part of our literature review, we would have excluded them. For example, some included a different definition of cancer survivors (i.e., differing from our definition of adults who had completed potentially curative treatment), and others did not appear to meet our inclusion criterion of interventions addressing two separate needs of cancer survivors. These differences do not imply that one approach is correct and the other wrong; rather, these two projects had different objectives. The review by Scott et al. identified interventions that may address the needs of individual survivors, but are not necessarily models of survivorship care. However, these differences further indicate the need to develop consensus and standards regarding definitions for “survivorship care models” as well as specifications for study populations or survivorship care models, types of care to be included, and outcomes to be assessed.

### Findings From KIs

Several KIs provided information on survivorship care models. One KI commented that survivorship clinics at academic institutions, which provide medical care as well as address psychosocial needs, are the only model she is aware of.

Another KI described a survivorship care model that has been funded by the LIVESTRONG Foundation and the NCI's Community Cancer Center Program. The initial survivorship visit is held on the same day as the first followup oncologist meeting. This survivorship visit is led by an advanced practice nurse and lasts 90 to 120 minutes. Components of the survivorship visit include developing a breast cancer treatment summary and care plan (for breast cancer survivors), assessing the survivor's immediate health needs and signs of recurrence and late effects of treatments, offering assistance with coordinating the patient's care among existing providers, and providing appropriate referrals. The KI and his colleagues have assessed changes in quality of life, satisfaction, and cancer concerns from baseline to 6 months for participants in this program.

Another KI described three survivorship care programs at her institution:

1. Cancer “transition” health care delivery program. This program is focused on breast cancer survivors but is expanding to other survivor populations. It involves a series of group medical visits with cancer survivor themes led by PCPs in partnership with oncologists. The program provides multidisciplinary, coordinated care delivery with an emphasis on cancer prevention and screenings. Survivors also complete an SCP.
2. One-time consultation with multiple providers. This approach assesses current needs and includes a care plan for preventative health care needs and surveillance. This consultation was a very resource-intensive model because it was not offered in conjunction with a patient's oncology visit. Plans are to have more of the screening and assessment of survivorship needs done in the disease site clinic; based on that screening and assessment, survivors will receive referrals to other providers to address those needs.
3. Adult survivors of childhood cancers program. This program involves one or two consultations with multiple health care providers. The survivors and PCPs receive a care summary that includes general health care prevention and surveillance strategies.

## GQ 4 Gaps in Knowledge and Future Research Needs for Models of Adult Cancer Survivorship Care

The literature includes information on a number of different types of survivorship care programs.58 Methods for developing and implementing survivorship care programs vary and depend on organizational and leadership support and the presence of an internal champion.57 Different settings include academic models, community practice models, and shared care.44 As noted in the discussion for GQ 3, little data exist on how many of these models have been implemented, evaluated, or compared with standard care. Few studies have evaluated the structural or process barriers or constraints to offering survivorship care, such as incentives and disincentives to continue surveillance of recurrence and resolution of side effects; reimbursement for survivorship care; survivors' perspectives on following up with their oncologists, with whom they may have become emotionally attached; and oncologists' perspectives on continued care provision for survivors who are doing well (which may provide emotional and economic benefits for oncologists). As survivorship care evolves, it will be important to include evaluation of the infrastructure needed for delivering optimal care as well as relevant outcomes.116,117 As we learn more about the needs and problems of long-term survivors, a one-size-fits-all model for survivorship care will likely not be as relevant as a triaged or tailored approach.

### Gaps in Knowledge

First, little is known about the added value of developing “models of care” for cancer survivors to add onto complex health care delivery systems, particularly in comparison with efforts to engage health care providers to deliver components of survivorship care within existing settings. In a related vein, the use of risk stratification to direct patients to primary care, specialist care, or a “tapering” regimen of specialist care (e.g., for patients with tumors with low risk of recurrence) is untested. Likewise, the relative merits (or potential harms) of care from a single provider versus continued collaboration and communication among multiple providers is unclear.

Second, studies need to adequately describe the model(s) being examined and provide more detailed information to assist in comparing results of one study with those of other studies and assessing the generalizability of any one model. When possible, studies of survivorship care models should compare their structures, processes, and outcomes with data from the “standard of care” (which, as discussed in the “Next Steps” section below, is not well defined) or from other survivorship models.

Third, studies of survivorship care, whether presented as models or not, need to provide additional data on the long-term or late effects of treatments received by adult cancer patients. This crucial information may be obtained from large epidemiological databases and longer-term extension of cancer clinical trials in addition to studies of survivorship care. This type of information may support better risk stratification of survivors within models based on projected recurrence and late effects and facilitate different types or levels of survivorship care based on individual risk profiles. For example, the needs of patients with low risk of recurrence or treatment effects (e.g., early-stage colon cancer) might be best served with a transition to a primary care model. On the other hand, patients at high risk for problems (e.g., bone marrow transplant survivors) might be better served in a disease-specific or multidisciplinary clinic. However, such risk stratification in survivorship care will be difficult without longitudinal data on survivors over long periods of time. Further, heterogeneity in the definition of survivors will also add challenges to this goal. A pragmatic approach may be to define a survivor as a person who has completed active acute cancer treatment and is receiving only observation or preventive/maintenance therapy when studying models of survivorship care.

Fourth, KIs identified a gap in understanding survivors' needs, especially in racial /ethnic minority populations. The literature reviews and interviews indicate that little information is available regarding development and implementation of culturally sensitive survivorship care models that would be acceptable and feasible for underserved patients in the United States.

Finally, an improved understanding of barriers to survivorship care is necessary. Regardless of the model adopted, barriers identified by KIs include financial incentives and disincentives, clinical information systems to identify candidates for survivorship care and to provide information, lack of organization support, and lack of health care provider training about survivorship issues. Additional barriers may reflect lack of patient awareness or interest/adherence in survivorship care programs and lack of provider knowledge regarding best processes for delivering coordinated care.

### Future Research Needs

Research is lacking on models of survivorship care, their components, and their context. As a result, a number of areas need to be explored, such as fostering organizational changes to deliver survivorship care, determining the frequency and length of care for survivors,57 measuring patient morbidity associated with followup appointments,92 developing evidence-based followup guidelines, and bridging the gap between oncologists and PCPs in delivering long-term followup care.58 Other future research needs were identified in a recently published survey of clinical leaders, administrators, and medical care providers from Cancer Research Network sites.14 This report identified gaps in evidence including potential advantages of using different models of care; long-term treatment effects; effectiveness of different approaches to surveillance; effectiveness and cost-effectiveness of different care models; evaluation of existing survivorship programs and tools; and the costs and benefits of survivorship care. In addition, different models of care and components of care need to be evaluated, particularly on measures of over or underuse of health care.57 Evidence-based surveillance plans currently exist for breast and colorectal cancers only and need to be expanded to other cancers. Long-term patient-reported outcomes should be collected to better predict higher and lower risk groups.

Understanding what contributes to organizational culture change to clinically support survivorship care is needed.

KIs and reviewers raised other questions, including the following:

- What are the needs of survivors over time?
- Given shortages among the oncology workforce, how should survivorship care be prioritized relate to acute cancer treatment?
- How can awareness of survivorship programs be improved among survivors, caregivers, and clinicians? Should survivorship care be imbedded in cancer care or provided as a separate service?
- How should an “oncology medical home” be defined? Is an oncology medical home important for survivorship care?
- Could a virtual patient navigator program facilitate transitions along the cancer continuum?
- What is the role of current and future financial incentives on survivorship care? For example, could financial incentives result in oncology providers discontinuing survivorship services if they receive greater reimbursement for providing curative treatment?
- How and when should rehabilitation professionals, gerontologists, or other subspecialists contribute to cancer survivorship care?
- What is the role of cultural and socio-economic context in influencing the feasibility and applicability of cancer survivorship care models?
- How should cancer survivorship care support or monitor long-term anti-cancer therapies (e.g., 10 years of adjuvant endocrine therapy)?
- What study designs are the most appropriate methods to evaluate survivorship programs?
- What key outcomes or endpoints should survivorship programs evaluate? Should programs evaluate costs routinely?
- What models of care have better outcomes?
- How do we optimize wellness in survivors? What is the role of self-management programs?

A broad range of ongoing research in cancer survivorship is underway, some of which is likely addressing these stated needs. For example, NCI has two Funding Opportunity Announcements (12-274 and 12-275) focused on survivorship care planning. Thus, the future research needs for survivorship care and gaps in knowledge are dynamic areas.