# Background

## The Increasing Population of Cancer Survivors and the Challenge of Transitioning From Cancer Treatment to Followup Care

As of January 2012, the United States had nearly 14 million cancer survivors, with 59 percent ages 65 years or older.1 The number of survivors is projected to grow to 18 million by 2022.^2^ Survivors (that is, patients who have completed active treatment) have unique physical, psychological, social, and spiritual health needs. Even as the oncology workforce is projected to experience substantial shortages,3-5 the number and needs of cancer survivors is projected to increase.

Relative to pediatric cancer survivors, adult survivors (i.e., survivors of adult-onset cancers) are understudied.6 Further, their health care needs differ from those of pediatric survivors—adult survivors may have an increased risk for comorbidities, presenting unique care coordination challenges. Consequently, this Technical Brief seeks to increase knowledge regarding survivorship care models for adult cancer survivors (19 years of age or older).

Cancer survivors have unique post-treatment needs, as these individuals may have higher risks of recurrence and secondary cancers; chronic or late-occurring effects of cancer or cancer treatment; comorbid conditions that may have been exacerbated by cancer treatment; and increased likelihood of preventable morbidity and mortality that can be reduced by health promotion activities. These unique needs highlight the importance of care programs specifically tailored for cancer survivors. As described in the Institute of Medicine (IOM) report “From Cancer Patient to Cancer Survivor: Lost in Transition,”7 survivorship care (i.e., the delivery of health care services specifically designed for cancer survivors) ideally includes (1) prevention of new (primary) and recurrent cancers and other late effects; (2) surveillance for recurrence or new cancers; (3) interventions for illnesses secondary to cancer and cancer treatment (including physical consequences of symptoms such as pain and fatigue, psychological distress experienced by cancer survivors and their caregivers, and concerns related to employment, insurance, and disability); and (4) coordination between specialists and primary care providers (PCPs)^*^ to ensure that all the health needs of survivors are met. Although these IOM recommendations form an important framework for examining cancer survivorship care, they are largely based on expert consensus.

* PCPs include physicians, nurse practitioners, and physician assistants.

Developing appropriate health care programs that provide needed supports and enhance relevant outcomes for individuals with cancer following completion of acute (i.e., potentially curative) cancer treatment can be difficult. Current cancer survivorship care often involves medical oncologists or other oncology health care providers following survivors for prolonged periods after treatment ends. Such a model may or may not represent the preferred approach for cancer survivors or for oncologists. Challenges to optimal care for cancer survivors (however “optimal” is defined) may include differing perspectives, lack of communication, or lack of clear expectations among PCPs and oncologists on their roles and responsibilities in delivering survivorship care.8,9 Limited evidence exists regarding the benefits of survivorship care programs, lack of knowledge among health care providers regarding the available evidence, and lack of consensus regarding which health care professionals should provide or coordinate survivorship care. These issues may result in inadequate care coordination, leading to the duplication or omission of prevention, detection, surveillance, or treatment services.10 This fragmentation of care may have significant adverse consequences for cancer survivors, including delayed detection of recurrences, suboptimal identification of symptom causes and treatments, overutilization of resources and care delivery inefficiencies, and worse outcomes including health-related quality of life. Furthermore, survivors may feel poorly informed regarding psychological, social, and sexual health issues,11 and their risk for recurrence of cancer12 and may be dissatisfied with care following cancer treatment.13 Certain survivorship care models, by involving additional clinical providers in the health care for an individual, may well lead to greater fragmentation of care and potential harms, especially if communication and coordination of care are not adequately addressed among providers and patients. Recent controversies regarding potential overscreening and overtreatment for cancer may suggest that survivorship care, if not appropriately coordinated and evidence-based, could result in inappropriate resource utilization and lack of benefit for certain populations of cancer survivors. Survivorship care programs may result in “care silos” that could undermine the coordination of care for patients with multiple chronic diseases.14 All of these issues highlight the importance of developing and evaluating evidence-based survivorship care models to address the multiple health care needs experienced by cancer survivors and to coordinate health care services among this diverse population.

The challenges associated with the transition of cancer survivors to followup care may be exacerbated by the concern among PCPs about their ability to deliver survivorship care,8 the rapidly growing number of cancer survivors in the United States, the projected shortage of oncologists and PCPs,3,15 and possible changes related to the Affordable Care Act16 (e.g., the development of Accountable Care Organizations may influence where and by whom cancer survivorship care is delivered17).

## Models of Care Intended To Enhance Outcomes and Provide Supports Among Cancer Survivors

An initial challenge for this project was to define a “model” of cancer survivorship care. The term “model” is frequently used in the cancer survivorship literature but is rarely (if ever) defined. Research shows general agreement that a model of survivorship care involves a broad and holistic approach to followup care for cancer survivors, addressing multiple needs. As discussed by Gilbert et al.,18 although approaches vary, all models are directed toward the common goal of improving the quality of care provided to cancer survivors by delivering comprehensive, coordinated, and tailored followup care.18, ^p.435^ Survivorship has various definitions and encompasses varying stages of the cancer survivor's experience; this report focuses only on individuals who have completed active cancer treatment and are transitioning from acute to more long-term medical care objectives.

Multiple published studies examine the effectiveness of programs addressing a single need among cancer survivors, such as support or counseling for psychological distress.19-42 For the purposes of this report, however, a program addressing a single need was not considered a model of survivorship care. Similarly, a program providing a single service to cancer survivors, such as facilitating surveillance for cancer recurrence or the development of new cancers, would not be considered a survivorship care model. For this report, we have defined a model of survivorship care as a program for cancer survivors that addresses two or more different health care needs as a minimum threshold for a model of care.

In this report, we refer to model “components” as the four categories of survivorship care identified by the IOM report From Cancer Patient to Cancer Survivor: Lost in Transition,7 namely, prevention, surveillance, intervention, and coordination. Cancer survivors experience multiple health care needs within each of these categories. Further, multiple health care services may be necessary to address each need. To clarify this terminology, consider a program designed to provide foot care for cancer survivors. This program could involve multiple health care services, including care from orthopedists to assess and potentially treat bone and joint abnormalities, podiatrists to diagnosis problems and potentially provide treatments including orthotics, and physical therapists to recommend exercises. However, all of these services focus on a single need: foot problems among cancer survivors. This hypothetical program does incorporate multiple health care providers and services, but we would not consider it a model of survivorship care because it addresses a single need only.

Cancer survivorship care will likely not have a “one size fits all” model. Many factors may influence which model will be most effective for a given situation, such as the number and type of survivors being served; available health care providers, services, and resources; risk of recurrence and level of symptoms or ongoing problems following cancer treatment; and patient preference regarding the type and source of survivorship care. Survivorship care models will need to be tailored based on all of these factors.

Different models of survivorship care have been described; a subset of the characteristics of these models is discussed in the Guiding Questions (GQs) below. Types of survivorship care models include community-based shared-care models, academically based comprehensive survivor program models, nurse practitioner-led shared care, and multidisciplinary programs for high-risk populations.43 These models are based on the providers delivering the care and the structure of the program or services being offered. For example, an academically based program may be offered for specific disease groups, although such a program may not be possible in other settings. Resources for survivors may be offered within a program or as separately available services within the community to address unmet needs. For example, a comprehensive survivorship program may offer exercise, weight management, and smoking cessation programs, or a smaller program may partner with local health clubs, exercise centers, and other organizations to offer such programs for survivors.

According to a recent report on survivorship care from the American Society for Clinical Oncology, “Because no uniform standards for the care of survivors exist, significant efforts are required to understand the needs of survivors and to develop models of comprehensive, coordinated care that meet those needs.”44, ^p.2^ As discussed in this American Society for Clinical Oncology report, additional research is needed to “expand the evidence base required to define optimal care delivery, including the type or components of care delivered, the manner in which that care is delivered and by whom, and the efficacy of the various models of care.”44, ^p.2^

A number of previous studies have described different models for delivering survivorship care and summarized research efforts in this area.7,44,45 However, few publications have described the process or outcomes of survivorship care models, or even specified the key outcomes that survivorship care should address. Therefore, the purpose of this Technical Brief is to describe different existing and proposed models of and services for survivorship care to promote understanding of the differences in care delivery and survivor outcomes associated with these models. The Technical Brief will also present information on studies of survivorship care models, explore the breadth of information available on these models and gaps in this literature, discuss potential issues that are important to key stakeholders, and identify areas of future research needs.

## Guiding Questions

The Guiding Questions (GQs) and subquestions that we used to collect information from published studies and Key Informants (KIs) are listed below and will be explored in this Technical Brief.

1. Overview of cancer survivorship care
  - What different models of cancer survivorship care have been most widely used?
  - What are the components of cancer survivorship care?
  - What is the nature of usual care for survivors of cancer?
  - What are the potential advantages and disadvantages of these models, when compared with one another and with usual care?
  - What are the potential safety issues and harms?
2. Context in which cancer survivorship care is used
  - What information do patients, clinical care providers, or other decisionmakers receive about survivorship programs or components of those programs?
  - How do models of care vary based on the following:
    ○ Setting?
    ○ Organizational structure?
    ○ Provider type and responsibilities of varying provider types in medical care for survivors, including providers involved in the patient transition from acute cancer treatment to ongoing survivorship?
    ○ Payment considerations?
    ○ Patient characteristics such as age, race/ethnicity, cancer type, stage of disease, and other risk-stratification issues?
  - What associated supportive care resources are commonly incorporated in or needed for survivorship care programs?
  - How is risk stratification being (or could be) applied to cancer survivor programs?
  - What kinds of resources (e.g., health information technology) are available or needed to share information among health care providers and with patients?
  - What are important considerations for evaluating appropriate resource utilization, cost, quality of care, and outcomes for survivorship programs?
  - How widely is survivorship care offered? For how long?
  - What kinds of training and staffing are required? What modifications to current training and staffing are in development?
3. Current evidence on cancer survivorship care
  - Characteristics of patients enrolled (age, race/ethnicity, cancer type, stage of disease)
  - Type of survivorship model, if defined
  - Setting
  - Organizational structure of the health care entities involved in survivorship care and in the transition from acute care treatment to survivorship care
  - Provider type
  - Payment considerations
  - Study design and size
  - Comparator used in comparative studies
  - Concurrent or previous treatments
  - Length of followup
  - Cost and resource utilization
  - Outcomes measured
  - Adverse events and unintended consequences of survivorship care
4. Gaps in knowledge and future research needs
  - What are the key decisional uncertainties?
  - What are the implications of the current level of diffusion or further diffusion of cancer survivorship care, given the current state of the evidence?
  - Are any models of survivorship care planned but not yet implemented?
  - What are the differences between existing models of survivorship care and new and emerging models of survivorship care?
  - What are possible areas of future research?