# Glossary of Terms

For the purposes of this Technical Brief, we define cancer survivor as an individual who has completed the majority or all of the active treatment for cancer (i.e., treatment with curative intent).

Survivorship care: A health care service or combination of services for cancer survivors that has one or more of these four components as defined by the Institute of Medicine (IOM) Committee on Cancer Survivorship: Improving Care and Quality of Life, Institute of Medicine and National Research Council. (From Cancer Patient to Cancer Survivor: Lost in Transition. Washington, DC: The National Academies Press, 2006, page 3):
  a. Prevention of recurrent and new cancers, and of other late effects;
  b. Surveillance for cancer spread, recurrence, or second cancers; assessment of medical and psychosocial late effects;
  c. Intervention for consequences of cancer and its treatment, for example: medical problems such as lymphedema and sexual dysfunction; symptoms, including pain and fatigue; psychological distress experienced by cancer survivors and their caregivers; and concerns related to employment, insurance, and disability; and
  d. Coordination between specialists and primary care providers to ensure that all of the survivor's health needs are met.
Survivorship Research: Cancer survivorship research encompasses the physical, psychosocial, and economic sequelae of cancer diagnosis and its treatment among both pediatric and adult survivors of cancer. It also includes within its domain issues related to health care delivery, access, and followup care, as they relate to survivors. Survivorship research focuses on the health and life of a person with a history of cancer beyond the acute diagnosis and treatment phase. It seeks to both prevent and control adverse cancer diagnosis and treatment-related outcomes such as late effects of treatment, second cancers, and poor quality of life; to provide a knowledge base regarding optimal followup care and surveillance of cancers; and to optimize health after cancer treatment. (http://dccps.nci.nih.gov/ocs/definitions.html)
Cancer Survivorship Program (American Cancer Society): “comprehensive set of services provided by multidisciplinary groups working together to ensure effective medical care, education and emotional support.”
Models of survivorship care: The construct behind the term “model” relates to the cohesiveness of a program that infers more than one service. In the Technical Brief, we describe various types of models found in the literature.
  a. Consultative model: the patient is primarily seen by primary care or survivorship care team, but periodically or on an as-needed basis refers to the oncology team for services.
  b. Multidisciplinary clinic: specialty (i.e., oncology) clinics coordinate with primary care and other medical service clinics to provide survivorship care.
  c. Integrated care model: each member of the patient's survivorship care experience communicates with each other and within a commonly agreed-upon system of care that establishes pre-determined roles (may share features with shared-care).
  d. Transition to primary care: the patient moves from predominantly oncology team care during active treatment to primary care for survivorship services.
  e. Shared-care model: the primary care team and the oncology team both provide health care to the cancer survivor (may share features with integrated care). Does not have to occur in an integrated system.
  f. Survivorship care plan (SCP): medically guided instructions for patient care during the survivorship stage based on an assessment of patient needs.
  g. Patient navigator: a lay/peer health partner who serves as a resource to the patient about survivorship care and as a liaison between the patient and the medical team and services.