# Evidence Tables

Evidence Table 1 Study characteristics—physician-led survivorship care models

Evidence Table 2 Study characteristics—nurse-led survivorship care models

Evidence Table 3 Study characteristics—survivorship care models in which SCP development is a key component

Evidence Table 4 Study characteristics—survivorship care models comparing group versus individual counseling

Evidence Table 5 Intervention characteristics—physician-led survivorship care models

Evidence Table 6 Intervention characteristics—nurse-led survivorship care models

Evidence Table 7 Intervention characteristics—survivorship care models focused on SCP development

Evidence Table 8 Intervention characteristics—survivorship care models comparing individual versus group counseling

Evidence Table 9 Patient characteristics

Evidence Table 10 Outcomes

## References

1 Cannon AJ, Darrington DL, McIlvain HE, et al. Association of number of follow-up providers with outcomes in survivors of hematologic malignancies. Leuk Lymphoma. Oct. 2010;51(10):1862-9. [pmid: 20858098].
2 Kokko R, Hakama M, Holli K. Follow-up cost of breast cancer patients with localized disease after primary treatment: a randomized trial. Breast Cancer Res Treat. Oct. 2005;93(3):255-60. [pmid: 16132530].
3 Wattchow DA, Weller DP, Esterman A, et al. General practice vs surgical-based follow-up for patients with colon cancer: randomised controlled trial. Br J Cancer. Apr. 24. 2006;94(8):1116-21. [pmid: 16622437].
4 Gates P, Seymour JF, Krishnasamy M. Insights into the development of a nurse-led survivorship care intervention for long-term survivors of Hodgkin lymphoma. Aust J Can Nurs. Jun. 2012;13(1):4-10.
5 Knowles G, Sherwood L, Dunlop MG, et al. Developing and piloting a nurse-led model of follow-up in the multidisciplinary management of colorectal cancer. Eur J Oncol Nurs. Jul. 2007;11(3):212-23. discussion 24-7. [pmid: 17188938].
6 Curcio KR, Lambe C, Schneider S, et al. Evaluation of a cancer survivorship protocol: transitioning patients to survivors. Clin J Oncol Nurs. Aug. 2012;16(4):400-6. [pmid: 22842691].
7 Grunfeld E, Julian JA, Pond G, et al. Evaluating survivorship care plans: results of a randomized, clinical trial of patients with breast cancer. J Clin Oncol. Dec. 20. 2011;29(36):4755-62. [pmid: 22042959].
8 Jefford M, Lotfi-Jam K, Baravelli C, et al. Development and pilot testing of a nurse-led posttreatment support package for bowel cancer survivors. Cancer Nurs. May-Jun. 2011;34(3):E1-10. [pmid: 21045754].
9 Naumann F, Munro A, Martin E, et al. An individual-based versus group-based exercise and counselling intervention for improving quality of life in breast cancer survivors. A feasibility and efficacy study. Psychooncology. Oct. 2012;21(10):1136-9. [pmid: 21726017].