# List of Excluded Studies

## (EXC1)—Wrong design

1 Collins RF, Bekker HL, Dodwell DJ. Follow-up care of patients treated for breast cancer: a structured review. Cancer Treat Rev. Feb. 2004;30(1):19-35. [pmid: 14766124].
2 Howard-Ruben J. Nurses help patients thrive and survive from diagnosis to treatment and beyond. ONS News. Jun. 4. 2005;20(6):1-6. [pmid: 15997995].
3 Jacobsen PB. Clinical practice guidelines for the psychosocial care of cancer survivors: current status and future prospects. Cancer. Sep. 15. 2009;115(18 Suppl):4419-29. [pmid: 19731353].
4 Jersild S. Programs work toward transitioning survivors to primary care. Oncology (Williston Park). Apr. 2007;21(4 Suppl):40-3. [pmid: 17508501].
5 Katz A. Breast cancer and women's sexuality. Am J Nurs. Apr. 2011;111(4):63-7. [pmid: 21451301].
6 Mitka M. Young adult cancer survivors face barriers to receiving primary care. JAMA. Oct. 24. 2012;308(16):1618-9. [pmid: 23093148].
7 Smith S, Landier W, Francisco L, et al. Development of a customizable, health promotion-oriented prostate cancer survivorship care plan. Oncol Nurs Forum. 2009;36(3):19-20. [pmid: 19136335].
8 Vanchani C, Hampshire MK, Hill-Kayser C, et al. The essential role of nurses in the development and utilization of an online cancer survivorship care plan. Oncol Nurs Forum. 2009;36(3):6.
9 Goroncy N, Wheeler G, Dwyer M, et al. Sharing the care: an innovative health program for childhood and adult cancer survivors between the late effects clinic at Peter Maccallum Cancer Centre and their GP's. Pediatr Blood Cancer. 2011;57(5):826.
10 Juth V, Cohen Silver R, Sender L, et al. Stressors of pediatric cancer care: the influence of interpersonal interactions. Clin Transl Sci. 2011;4(2):131.
11 Rogers P, Barr RD, Schacter B. The Canadian task force on adolescents and young adults (AYA) with cancer; a process for change. Pediatr Blood Cancer. 2011;57(5):839.
12 Sullivan M, Yallop K, Simpson R, et al. Leap-it-a passport to health; an integrated late effects assessment programme and electronic health passport for long term follow-up of child cancer survivors in New Zealand. Pediatr Blood Cancer. 2011;57(5):710.

## (EXC2)—Wrong or No Intervention

1 Absolom K, Eiser C, Michel G, et al. Follow-up care for cancer survivors: views of the younger adult. Br J Cancer. Aug. 18. 2009;101(4):561-7. [pmid: 19638979].
2 Barg FK, Cronholm PF, Straton JB, et al. Unmet psychosocial needs of Pennsylvanians with cancer: 1986-2005. Cancer. Aug. 1. 2007;110(3):631-9. [pmid: 17592828].
3 Becker H, Rechis R, Kang SJ, et al. The post-treatment experience of cancer survivors with pre-existing cardiopulmonary disease. Support Care Cancer. Sep. 2011;19(9):1351-5. [pmid: 20658347].
4 Belkora J, Katapodi M, Moore D, et al. Evaluation of a visit preparation intervention implemented in two rural, underserved counties of Northern California. Patient Educ Couns. Dec. 2006;64(1-3):350-9. [pmid: 16904859].
5 Binkley JM, Harris SR, Levangie PK, et al. Patient perspectives on breast cancer treatment side effects and the prospective surveillance model for physical rehabilitation for women with breast cancer. Cancer. Apr. 15. 2012;118(8 Suppl):2207-16. [pmid: 22488695].
6 Bishop MM, Lee SJ, Beaumont JL, et al. The preventive health behaviors of long-term survivors of cancer and hematopoietic stem cell transplantation compared with matched controls. Biol Blood Marrow Transplant. Feb. 2010;16(2):207-14. [pmid: 19781657].
7 Brennan ME, Butow P, Marven M, et al. Survivorship care after breast cancer treatment–experiences and preferences of Australian women. Breast. Jun. 2011;20(3):271-7. [pmid: 21236671].
8 Cappiello M, Cunningham RS, Knobf MT, et al. Breast cancer survivors: information and support after treatment. Clin Nurs Res. Nov. 2007;16(4):278-93. discussion 94-301. [pmid: 17991908].
9 Casillas J, Syrjala KL, Ganz PA, et al. How confident are young adult cancer survivors in managing their survivorship care? A report from the LIVESTRONG Survivorship Center of Excellence Network. J Cancer Surviv. Dec. 2011;5(4):371-81. [pmid: 22042661].
10 Clauser SB, Arora NK, Bellizzi KM, et al. Disparities in HRQOL of cancer survivors and non-cancer managed care enrollees. Health Care Financ Rev. Summer. 2008;29(4):23-40. [pmid: 18773612].
11 Hill-Kayser CE, Vachani C, Hampshire MK, et al. High level use and satisfaction with internet-based breast cancer survivorship care plans. Breast J. Jan-Feb. 2012;18(1):97-9. [pmid: 22098063].
12 Husson O, Holterhues C, Mols F, et al. Melanoma survivors are dissatisfied with perceived information about their diagnosis, treatment and follow-up care. Br J Dermatol. Oct. 2010;163(4):879-81. [pmid: 20854404].
13 Jones JM, Ferguson S, Edwards E, et al. Experiences of care delivery: endometrial cancer survivors at end of treatment. Gynecol Oncol. Mar. 2012;124(3):458-64. [pmid: 22079362].
14 Keating NL, Landrum MB, Guadagnoli E, et al. Surveillance testing among survivors of early-stage breast cancer. J Clin Oncol. Mar. 20. 2007;25(9):1074-81. [pmid: 17369571].
15 Khan NF, Ward A, Watson E, et al. Long-term survivors of adult cancers and uptake of primary health services: a systematic review. Eur J Cancer. Jan. 2008;44(2):195-204. [pmid: 18035534].
16 Lauver DR, Connolly-Nelson K, Vang P. Stressors and coping strategies among female cancer survivors after treatments. Cancer Nurs. Mar-Apr. 2007;30(2):101-11. [pmid: 17413775].
17 Lavoie Smith EM, Skalla K, Li Z, et al. Assessing cancer survivors' needs using web-based technology: a pilot study. Comput Inform Nurs. Feb. 2012;30(2):71-81. [pmid: 22258317].
18 Mandelblatt JS, Lawrence WF, Cullen J, et al. Patterns of care in early-stage breast cancer survivors in the first year after cessation of active treatment. J Clin Oncol. Jan. 1. 2006;24(1):77-84. [pmid: 16382116].
19 Marbach TJ, Griffie J. Patient preferences concerning treatment plans, survivorship care plans, education, and support services. Oncol Nurs Forum. May. 2011;38(3):335-42. [pmid: 21531683].
20 McCabe MS, Jacobs LA. Clinical update: survivorship care–models and programs. Semin Oncol Nurs. Aug. 2012;28(3):e1-8. [pmid: 22846488].
21 McNees P. Technology application to assist young survivors with fertility concerns. Semin Oncol Nurs. Nov. 2009;25(4):284-7. [pmid: 19879435].
22 Mitchell TL, Yakiwchuk CV, Griffin KL, et al. Survivor dragon boating: a vehicle to reclaim and enhance life after treatment for breast cancer. Health Care Women Int. Feb. 2007;28(2):122-40. [pmid: 17364976].
23 Tan AS, Moldovan-Johnson M, Parvanta S, et al. Patient-provider information engagement improves adherence to colorectal cancer surveillance after curative treatment: results from a longitudinal study. Oncologist. 2012;17(9):1155-62. [pmid: 22858794].
24 Walton LM, Reeve J, Brown PM, et al. Gynaecologic cancer patients' needs and experiences of supportive health services in New Zealand. Psychooncology. Feb. 2010;19(2):201-8. [pmid: 19253918].
25 Wenzel J, Jones R, Klimmek R, et al. Exploring the role of community health workers in providing cancer navigation: perceptions of African American older adults. Oncol Nurs Forum. May. 1. 2012;39(3):E288-98. [pmid: 22543400].
26 Howell D, Hack TF, Oliver TK, et al. Survivorship services for adult cancer populations: a pan-Canadian guideline. Current Oncology. 2011;18(6):e265-e81. [pmid: 22184494].
27 Alliance MC. Cancer Survivor Care Plan. Minnesota Cancer Alliance, Minnesota Dept. of Health.
28 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology (NCCN Guidelines): Survivorship [Presentation]. 2013. June 11, 2013. https://subscriptions.nccn.org/gl_login.aspx?ReturnURL=http://www.nccn.org/professionals/physician_gls/pdf/survivorship.pdf.

## (EXC3)—Wrong Population

1 Bains M, Munir F, Yarker J, et al. Return-to-work guidance and support for colorectal cancer patients: a feasibility study. Cancer Nurs. Nov-Dec. 2011;34(6):E1-12. [pmid: 21372705].
2 Bosompra K, Ashikaga T, O'Brien PJ, et al. Knowledge about preventing and managing lymphedema: a survey of recently diagnosed and treated breast cancer patients. Patient Educ Couns. Jun. 2002;47(2):155-63. [pmid: 12191539].
3 Carney ME, Lancaster JM, Ford C, et al. A population-based study of patterns of care for ovarian cancer: who is seen by a gynecologic oncologist and who is not?. Gynecol Oncol. Jan. 2002;84(1):36-42. [pmid: 11748973].
4 Choi KH, Park JH, Park SM. Cancer patients' informational needs on health promotion and related factors: a multi-institutional, cross-sectional study in Korea. Support Care Cancer. Oct. 2011;19(10):1495-504. [pmid: 20694821].
5 Chung MH, Chao TY, Chou KR, et al. Health-promoting lifestyle factors of cancer survivors in Taiwan. Cancer Nurs. May-Jun. 2009;32(3):E8-E14. [pmid: 19295426].
6 Cotterell P, Harlow G, Morris C, et al. Service user involvement in cancer care: the impact on service users. Health Expect. Jun. 2011;14(2):159-69. [pmid: 21029279].
7 Sweeney L, Halpert A, Waranoff J. Patient-centered management of complex patients can reduce costs without shortening life. Am J Manag Care. Feb. 2007;13(2):84-92. [pmid: 17286528].
8 Tamminga SJ, de Boer AG, Bos MM, et al. A hospital-based work support intervention to enhance the return to work of cancer patients: a process evaluation. J Occup Rehabil. Dec. 2012;22(4):565-78. [pmid: 22699884].
9 Yi M, Park EY. Effects of breast health education conducted by trained breast cancer survivors. J Adv Nurs. May. 2012;68(5):1100-10. [pmid: 21880060].
10 van de Poll-Franse LV, Nicolaije KAH, Vos MC, et al. The impact of a cancer Survivorship Care Plan on gynecological cancer patient and health care provider reported outcomes (ROGY Care): study protocol for a pragmatic cluster randomized controlled trial. Trials. 2011;12(1):256-63. [pmid: 22141750].
11 Annunziata MA, Giovannini L, Muzzatti B, et al. Sexuality and intimacy in long-term cancer survivors: Explorative results from the first Italian cancer survivor clinic. Psychooncology. 2011;20:271.
12 Konopacki J, Porcher R, Robin M, et al. Long-term follow-up of allogeneic hematopoietic stem cell transplantation in patients with severe alpastic anemia after cyclophosphamide plus antithymocyte globulin conditioning regimen. Blood. 2011;118(21).
13 Trevino K, Fasciano K, Block S, et al. Young adults with advanced cancer: the relationship between social support and psychological well-being. Psychooncology. 2012;21:6-7.
14 Nieuwenhuijsen K, Bos-Ransdorp B, Uitterhoeve LL, et al. Enhanced provider communication and patient education regarding return to work in cancer survivors following curative treatment: a pilot study. J Occup Rehabil. Dec. 2006;16(4):647-57. [pmid: 17063404].
15 Rao AV, Hsieh F, Feussner JR, et al. Geriatric evaluation and management units in the care of the frail elderly cancer patient. J Gerontol A Biol Sci Med Sci. Jun. 2005;60(6):798-803. [pmid: 15983186].

## (EXC4)—Wrong Outcome Or No Outcome Of Interest

1 Cimprich B, Janz NK, Northouse L, et al. Taking CHARGE: a self-management program for women following breast cancer treatment. Psychooncology. Sep. 2005;14(9):704-17. [pmid: 15651055].
2 Curcio KR, Lambe C, Schneider S, et al. Evaluation of a cancer survivorship protocol: transitioning patients to survivors. Clin J Oncol Nurs. Aug. 2012;16(4):400-6. [pmid: 22842691].
3 Faul LA, Rivers B, Shibata D, et al. Survivorship care planning in colorectal cancer: feedback from survivorship and providers. J Psychosoc Oncol. Mar. 2012;30(2):198-216. [pmid: 22416956].
4 Flood KL, Carroll MB, Le CV, et al. Polypharmacy in hospitalized older adult cancer patients: experience from a prospective, observational study of an oncology-acute care for elders unit. Am J Geriatr Pharmacother. Jun. 2009;7(3):151-8. [pmid: 19616183].
5 Walsh-Burke K, Marcusen C. Self-advocacy training for cancer survivors. The Cancer Survival Toolbox. Cancer Pract. Nov-Dec. 1999;7(6):297-301. [pmid: 10732527].
6 Wanchai A, Armer JM, Stewart BR. Performance care practices in complementary and alternative medicine by Thai breast cancer survivors: an ethnonursing study. Nurs Health Sci. Sep. 2012;14(3):339-44. [pmid: 22950615].
7 Steinglass P, Ostroff JS, Steinglass AS. Multiple family groups for adult cancer survivors and their families: a 1-day workshop model. Fam Process. Sep. 2011;50(3):393-409. [pmid: 21884077].

## (EXC5)—Single Service Only-Single Need/Multiple Providers

1 Campbell KL, Van Patten CL, Neil SE, et al. Feasibility of a lifestyle intervention on body weight and serum biomarkers in breast cancer survivors with overweight and obesity. J Acad Nutr Diet. Apr. 2012;112(4):559-67. [pmid: 22709706].
2 Glynne-Jones R, Chait I, Thomas SF. When and how to discharge cancer survivors in long term remission from follow-up: the effectiveness of a contract. Clin Oncol (R Coll Radiol). 1997;9(1):25-9. [pmid: 9039810].
3 Grunfeld E, Levine MN, Julian JA, et al. Randomized trial of long-term follow-up for early-stage breast cancer: a comparison of family physician versus specialist care. J Clin Oncol. Feb. 20. 2006;24(6):848-55. [pmid: 16418496].
4 Kinney CK, Rodgers DM, Nash KA, et al. Holistic healing for women with breast cancer through a mind, body, and spirit self-empowerment program. J Holist Nurs. Sep. 2003;21(3):260-79. [pmid: 14528850].
5 Kwok C, Ho M. Development and evaluation of a culturally sensitive support group programme for Chinese-Australian women with breast cancer: a pilot study. Eur J Cancer Care (Engl). Nov. 2011;20(6):795-802. [pmid: 21771132].
6 van Weert E, May AM, Korstjens I, et al. Cancer-related fatigue and rehabilitation: a randomized controlled multicenter trial comparing physical training combined with cognitive-behavioral therapy with physical training only and with no intervention. Phys Ther. Oct. 2010;90(10):1413-25. [pmid: 20651011].
7 Waltman NL, Twiss JJ, Ott CD, et al. Testing an intervention for preventing osteoporosis in postmenopausal breast cancer survivors. J Nurs Scholarsh. 2003;35(4):333-8. [pmid: 14735675].
8 Waltman NL, Twiss JJ, Ott CD, et al. The effect of weight training on bone mineral density and bone turnover in postmenopausal breast cancer survivors with bone loss: a 24-month randomized controlled trial. Osteoporos Int. Aug. 2010;21(8):1361-9. [pmid: 19802506].
9 Zibecchi L, Greendale GA, Ganz PA. Comprehensive menopausal assessment: an approach to managing vasomotor and urogenital symptoms in breast cancer survivors. Oncol Nurs Forum. 2003;30(3):393-407. [pmid: 12719740].

## (EXC5)—Single Service Only-Single Need/Single Provider

1 Hypnosis helps reduce hot flashes in breast cancer survivors. Harv Womens Health Watch. Feb. 2009;16(6):3. [pmid: 19297743].
2 Amsterdam A, Krychman ML. Sexual dysfunction in patients with gynecologic neoplasms: a retrospective pilot study. J Sex Med. Jul. 2006;3(4):646-9. [pmid: 16776780].
3 Ashing-Giwa KT. Enhancing physical well-being and overall quality of life among underserved Latina-American cervical cancer survivors: feasibility study. J Cancer Surviv. Sep. 2008;2(3):215-23. [pmid: 18712607].
4 Benton B, Norton C, Lindsay JO, et al. Can nurses manage gastrointestinal symptoms arising from pelvic radiation disease?. Clin Oncol (R Coll Radiol). Oct. 2011;23(8):538-51. [pmid: 21530194].
5 Butt CM. Hope in patients with cancer transitioning to survivorship: the mid-life directions workshop as a supportive intervention. Oncol Nurs Forum. May. 1. 2012;39(3):E269-74. [pmid: 22543398].
6 Heidrich SM, Brown RL, Egan JJ, et al. An individualized representational intervention to improve symptom management (IRIS) in older breast cancer survivors: three pilot studies. Oncol Nurs Forum. May. 2009;36(3):E133-43. [pmid: 19403441].
7 Hundepool AC, Dumans AG, Hofer SO, et al. Rehabilitation after mandibular reconstruction with fibula free-flap: clinical outcome and quality of life assessment. Int J Oral Maxillofac Surg. Nov. 2008;37(11):1009-13. [pmid: 18657394].
8 Vallance JK, Courneya KS, Plotnikoff RC, et al. Analyzing theoretical mechanisms of physical activity behavior change in breast cancer survivors: results from the activity promotion (ACTION) trial. Ann Behav Med. Apr. 2008;35(2):150-8. [pmid: 18347895].
9 Vallance JK, Courneya KS, Plotnikoff RC, et al. Randomized controlled trial of the effects of print materials and step pedometers on physical activity and quality of life in breast cancer survivors. J Clin Oncol. Jun. 10. 2007;25(17):2352-9. [pmid: 17557948].
10 Angell KL, Kreshka MA, McCoy R, et al. Psychosocial intervention for rural women with breast cancer: The Sierra-Stanford Partnership. J Gen Intern Med. 2003;18(7):499-507. [pmid: 12848832].
11 Pekmezi DW, Demark-Wahnefried W. Updated evidence in support of diet and exercise interventions in cancer survivors. Acta Oncologica. 2011;50(2):167-78. [pmid: 21091401].
12 Schultz DM, Mir M. Cancer180: because when cancer strikes, life does a 180. Psycho-Oncol. 2012;21:7.
13 Park JH, Bae SH, Jung YS, et al. Quality of life and symptom experience in breast cancer survivors after participating in a psychoeducational support program: a pilot study. Cancer Nurs. Jan-Feb. 2012;35(1):E34-41. [pmid: 21760491].
14 Sherman KA, Heard G, Cavanagh KL. Psychological effects and mediators of a group multi-component program for breast cancer survivors. J Behav Med. Oct. 2010;33(5):378-91. [pmid: 20502954].
15 Shields CG, Ziner KW, Bourff SA, et al. An intervention to improve communication between breast cancer survivors and their physicians. J Psychosoc Oncol. Nov. 2010;28(6):610-29. [pmid: 21058159].

## Additional Excludes from August 2013 Search

1 Alterowitz R, Alterowitz B. Women, sexuality and the cancer journey. J Sex Med. 2013;10:145.
2 Alterowitz R, Alterowitz B. Sexuality and successful survivorship-a paradigm to helpimprove quality of life. J Sex Med. 2013;10:150.
3 Anderson CB, Barocas DA. Delivering high-quality care to prostate cancer survivors. Cancer. 2013.
4 Anllo LM. Successful psychotherapy for female sexual dysfunction in a young woman with endometrial cancer: When medicine is not the answer. J Sex Med. 2013;10:149.
5 Aschwanden C. For cancer patients, rehab can start even before treatment does. Washington Post. July. 30. 2013:2013.
6 Ashing KT, Rosales M, Serrano M, et al. Developing a culturally and linguistically responsive survivorship care plan for breast cancer. J Clin Oncol. 2013;31(15).
7 Ashing-Giwa K. Survivorship Care Planning for At Risk Breast Cancer Survivors: A Focus on Latina-, Asian-, African-, and European Americans. City of Hope Medical Center. Duarte, California. 2013.
8 Avino RJ, Allam ES, Chen L, et al. Breast cancer patient surveillance following curative-intent treatment: variation among metropolitan statistical areas. J Clin Oncol. 2013;31(15).
9 Avino RJ, Margenthaler JA, Allam ES, et al. Patient surveillance after breast cancer treatment: variation among metropolitan statistical areas. J Surg Res. 2013;179(2).
10 Barbour RS, Porter MA, Peddie VL, et al. Counselling in the context of fertility and cancer: some sociological insights. Human Fertility. 2013;16(1):54-8. [pmid: 23509856].
11 Bezy O. From psychological vulnerability to psychopathological risks in the “post-cancer” period. Psycho-Oncologie. 2013;7(1):30-4.
12 Blair CK, Madan-Swain A, Locher JL, et al. Harvest for health gardening intervention feasibility study in cancer survivors. Acta Oncol. 2013;52(6):1110-8. [pmid: 23438359].
13 Brothers BM, Easley A, Salani R, et al. Do survivorship care plans impact patients' evaluations of care? A randomized evaluation with gynecologic oncology patients. Gynecol Oncol. Jun. 2013;129(3):554-8. [pmid: 23474344].
14 Burke CA. Younger Women with Breast Cancer: The Impact of Self-Directed Learning on Quality of Life during Chemotherapy [D.B.A.]. Ann Arbor. Wilmington University (Delaware). 2013.
15 Caceres A. Adverse changes in body composition of cancer survivors with BRCA mutations. J Clin Oncol. 2013;31(15).
16 Calip GS, Boudreau DM, Loggers ET. Changes in adherence to statins and subsequent lipid profiles during and following breast cancer treatment. Breast Cancer Res Treat. 2013;138(1):225-33. [pmid: 23358904].
17 Cox A, Faithfull S. ‘They're survivors physically but we want them to survive mentally as well': health care professionals’ views on providing potential late effect information. Support Care Cancer. 2013;21(9):2491-7. [pmid: 23609926].
18 Cullen P. GPs demand urgent talks on breast cancer survivor care plans. Irish Times. 2013. June. 18. 2013.
19 Denlinger C. Adherence to Survivorship Care Guidelines in Health Care Providers for Non-Small Cell Lung Cancer and Colorectal Cancer Survivor Care. Philadelphia, PA. Fox Chase Cancer Center. 2013.
20 Di Genesio Pagliuca M, Turri L, Munoz F, et al. Patterns of practice in the radiation therapy management of rectal cancer: survey of the Interregional Group Piedmont, Valle d'Aosta and Liguria of the “Associazione Italiana di Radioterapia Oncologica (AIRO)”. Tumori. Jan-Feb. 2013;99(1):61-7. [pmid: 23549002].
21 Donnelly L. NHS struggling to cope with millions in need after cancer. Daily Telegraph. 2013. July. 19. 2013.
22 Faiman B, Tariman J, Bilotti E, et al. Health maintenance and preventive care practices of myeloma survivors. Clinical Lymphoma, Myeloma and Leukemia. 2013;13:S200.
23 Faiul L. Survivorship Care Planning and Outcomes in Older Women with Breast Cancer. Washington, DC. Georgetown University. 2013.
24 Forsythe LP, Parry C, Alfano CM, et al. Gaps in survivorship care plan delivery and potential benefits to survivorship care. J Clin Oncol. 2013;31(15).
25 Ganz PA. Cognitive Rehabilitation Group Intervention for Breast Cancer Survivors. Los Angeles, CA. Jonsson Comprehensive Cancer Center. 2013.
26 Garcia L, Viveros L, Kagawa-Singer M, et al. Reintegration of cervical cancer survivors: A survey of women's health providers. Gynecol Oncol. 2013;130(1):e147.
27 Hagan TL, Donovan HS. Ovarian cancer survivors' experiences of self-advocacy: a focus group study. Oncol Nurs Forum. Mar. 2013;40(2):140-7. [pmid: 23454476].
28 Hartzell RMH, Goldstein IG, Goldstein SWG. Treating cancer survivors for their sexual dysfunction using a biopsychosocial approach. J Sex Med. 2013;10:153.
29 Hill-Kayser C, Vachani C, Hampshire MK, et al. Providing cancer survivorship care plans for Spanish language speakers: Overall use and satisfaction patterns. J Clin Oncol. 2013;31(15).
30 Hill-Kayser CE, Vachani CC, Hampshire MK, et al. Impact of internet-based cancer survivorship care plans on health care and lifestyle behaviors. Cancer. 2013. Aug. 6. [pmid: 23922002].
31 Holland L. What Are Your Recommendations Regarding Survivorship Care Plans?. ONS Connect. 2013;28(1):21. [pmid: 23495522].
32 Hornberger J, Degtiar I, Gutierrez H, et al. Cost-effectiveness of gene-expression profiling for tumor-site origin. Value Health. Jan-Feb. 2013;16(1):46-56. [pmid: 23337215].
33 Inoue-Choi M, Lazovich D, Prizment AE, et al. Adherence to the World Cancer Research Fund/American Institute for Cancer Research recommendations for cancer prevention is associated with better health-related quality of life among elderly female cancer survivors. J Clin Oncol. May. 10. 2013;31(14):1758-66. [pmid: 23569318].
34 Jacobs LA, Vaughn DJ. In the clinic. Care of the adult cancer survivor. Ann Intern Med. Jun. 4. 2013;158(11):ITC6-1. [pmid: 23732730].
35 Karvinen KH, Murray NP, Arastu H, et al. Stress reactivity, health behaviors, and compliance to medical care in breast cancer survivors. Oncol Nurs Forum. Mar. 2013;40(2):149-56. [pmid: 23448739].
36 Kondo S, Kondo M, Kondo A. Glycemia Control Using A1C Level in Terminal Cancer Patients with Preexisting Type 2 Diabetes. J Palliat Med. 2013;16(7):790-3. [pmid: 23448686].
37 Korner A, Drapeau M, Thombs BD, et al. Barriers and facilitators of adherence to medical advice on skin self-examination during melanoma follow-up care. BMC Dermatol. 2013;13:3. [pmid: 23448249].
38 Lane BR, Golan S, Eggener S, et al. Differential use of partial nephrectomy for intermediate and high complexity tumors may explain variability in reported utilization rates. J Urol. Jun. 2013;189(6):2047-53. [pmid: 23313207].
39 Leoni M, Sadacharan R, Louis D, et al. Variation among local health units in follow-up care of breast cancer patients in Emilia-Romagna, Italy. Tumori. Jan-Feb. 2013;99(1):30-4. [pmid: 23548996].
40 Llarena N, Nunez O, Kane A, et al. Effect of fertility concerns on tamoxifen use in young survivors of breast cancer. J Clin Oncol. 2013;31(15).
41 Loh SY, Chew SL, Quek KF. Physical activity engagement after breast cancer: Advancing the health of survivors. Health (1949-4998). 2013;5(5):838-46.
42 Maher EJ. Managing the consequences of cancer treatment and the English National Cancer Survivorship Initiative. Acta Oncol. 2013;52(2):225-32. [pmid: 23237053].
43 Marcus AC, Diefenbach MA, Stanton AL, et al. Cancer patient and survivor research from the cancer information service research consortium: a preview of three large randomized trials and initial lessons learned. J Health Commun. 2013;18(5):543-62. [pmid: 23448232].
44 McCarthy M. Internet-based therapy to improve sleep in rural breast cancer survivors. Denver, CO. University of Colorado. 2013.
45 Miedema B, Easley J, Robinson LM. Do current cancer follow-up care practices meet the needs of young adult cancer survivors in Canada? A qualitative inquiry. Curr Oncol. 2013;20(1):14-22. [pmid: 23443642].
46 Muls AC, Watson L, Shaw C, et al. Managing gastrointestinal symptoms after cancer treatment: A practical approach for gastroenterologists. Frontline Gastroenterology. 2013;4(1):57-68.
47 Nsofor VU, Okeke GC. Integrating sexual health into cancer care plans. J Sex Med. 2013;10:153.
48 Paget JT, Young KC, Wilson SM. Accurately costing unilateral delayed DIEP flap breast reconstruction. J Plast Reconstr Aesthet Surg. Jul. 2013;66(7):926-30. [pmid: 23664800].
49 Pereira M, Teixeira R. Portuguese Validation of FACES-IV in Adult Children Caregivers Facing Parental Cancer. Contemp Fam Ther. 2013;35(3):478-90.
50 Rechis R, Bann C, Nutt S, et al. Who is receiving survivorship care plans? Findings from the 2012 Livestrong survey. J Clin Oncol. 2013;31(15).
51 Richter S, AlMatar A, Lalani N, et al. Survivorship care in Canadian genitourinary oncology: toward a multidisciplinary perspective. J Clin Oncol. 2013;31(6).
52 Robin Yabroff K, Short PF, Machlin S, et al. Access to Preventive Health Care for Cancer Survivors. Am J Prev Med. 2013;45(3):304-12. [pmid: 23953357].
53 Roorda C, Berendsen AJ, Haverkamp M, et al. Discharge of breast cancer patients to primary care at the end of hospital follow-up: a cross-sectional survey. Eur J Cancer. May. 2013;49(8):1836-44. [pmid: 23453936].
54 Scott DA, Mills M, Black A, et al. Multidimensional rehabilitation programmes for adult cancer survivors. Cochrane Database of Systematic Reviews. 2013;(3).
55 Simmons CE, Wai E, Tyldesley S, et al. Risk of hospital-related morbidity among survivors of breast cancer in British Columbia, Canada. J Clin Oncol. 2013;31(15).
56 Singh-Carlson S, Nguyen SKA, Wong F. Perceptions of survivorship care among South Asian female breast cancer survivors. Curr Oncol. 2013;20(2):e80-e9. [pmid: 23559889].
57 Smyth C. Care crisis looms as half of Britons face cancer threat; NHS under pressure as survival rates soar. The Times. 2013. June. 7. 2013.
58 So WKW, Chan CWH, Choi KC, et al. Perceived unmet needs and health-related quality of life of Chinese cancer survivors at 1 year after treatment. Cancer Nurs. 2013;36(3):E23-E32. [pmid: 22964864].
59 Spoelstra SL, Given BA, Schutte DL, et al. Do Older Adults With Cancer Fall More Often? A Comparative Analysis of Falls in Those With and Without Cancer. Oncol Nurs Forum. 2013;40(2):E69-E78. [pmid: 23448747].
60 Stark JC. Perceived benefits of group music therapy for breast cancer survivors: Mood, psychosocial well-being, and quality of life. [Dissertation]. Ann Arbor. Michigan State University. 2012.
61 Sun CL, Kersey JH, Francisco L, et al. Burden of Morbidity in 10+ Year Survivors of Hematopoietic Cell Transplantation: Report from the Bone Marrow Transplantation Survivor Study. Biol Blood Marrow Transplant. 2013;19(7):1073-80. [pmid: 23583827].
62 Sun V. Survivorship Care Planning in Patients With Colorectal or Non-Small Cell Lung Cancer. Duarte, CA. City of Hope Medical Center. 2013.
63 Sutradhar R, Seow H, Earle C, et al. Modeling the Longitudinal Transitions of Performance Status in Cancer Outpatients: Time to Discuss Palliative Care. J Pain Symptom Manage. 2013;45(4):726-34. [pmid: 22940563].
64 Tang ST, Chang WC, Chen JS, et al. Course and predictors of depressive symptoms among family caregivers of terminally ill cancer patients until their death. Psychooncology. 2013;22(6):1312-8. [pmid: 22836818].
65 Thompson K, Dyson G, Holland L, et al. An Exploratory Study of Oncology Specialists' Understanding of the Preferences of Young People Living With Cancer. Soc Work Health Care. 2013;52(2/3):166-90. [pmid: 23521383].
66 Torzilli G, Belghiti J, Kokudo N, et al. A snapshot of the effective indications and results of surgery for hepatocellular carcinoma in tertiary referral centers: is it adherent to the EASL/AASLD recommendations?: an observational study of the HCC East-West study group. Ann Surg. May. 2013;257(5):929-37. [pmid: 23426336].
67 van de Poll-Franse LV, Nicolaije KA, Vos MC, et al. The impact of a cancer Survivorship Care Plan on gynecological cancer patient and health care provider reported outcomes (ROGY Care): study protocol for a pragmatic cluster randomized controlled trial. Trials. Dec. 5. 2011:256. [pmid: 22141750].
68 Van de Poll-Franse LV, Nicolaije KAH, Ezendam NPM, et al. The impact of an automatically generated survivorship care plan on patient reported outcomes (ROGY Care): Results of a pragmatic cluster randomized controlled trial among endometrial cancer patients. J Clin Oncol. 2013;31(15).
69 Van Steenbergen LN, Steur M, Lemmens VEPP, et al. Minimal excess mortality for long-term colon cancer survivors in the Netherlands 1989-2008. Eur J Cancer. 2013;49(3):585-92. [pmid: 22967727].
70 Virgo KS, Bromberek JL, Glaser A, et al. Health care policy and cancer survivorship. Cancer. 2013;119(SUPPL11):2187-99. [pmid: 23695931].
71 von Heymann-Horan AB, Dalton SO, Dziekanska A, et al. Unmet needs of women with breast cancer during and after primary treatment: a prospective study in Denmark. Acta Oncol. Feb. 2013;52(2):382-90. [pmid: 23320775].
72 Walter LC, Fung KZ, Kirby KA, et al. Five-year downstream outcomes following prostate-specific antigen screening in older men. JAMA Intern Med. May. 27. 2013;173(10):866-73. [pmid: 23588999].
73 Weaver K. Survivorship Care Planning and Communication for Rural Breast Cancer Survivors. Winston Salem, NC. Wake Forest University. 2013.
74 Wiljer D, Urowitz S, Jones J, et al. Exploring the use of the survivorship consult in providing survivorship care. Support Care Cancer. 2013;21(8):2117-24. [pmid: 23455454].
75 Yeom H, Heidrich SM. Relationships Between Three Beliefs as Barriers to Symptom Management and Quality of Life in Older Breast Cancer Survivors. Oncol Nurs Forum. 2013:E108-E18. [pmid: 23615144].
76 Zernicke KA, Campbell TS, Speca M, et al. The eCALM Trial-eTherapy for cancer appLying mindfulness: online mindfulness-based cancer recovery program for underserved individuals living with cancer in Alberta: protocol development for a randomized wait-list controlled clinical trial. BMC Complement Altern Med. 2013;13:34. [pmid: 23414206].

## Peer Reviewer and Public Commenters Handsearch Exclusions

1 Bennett JA, Winters-Stone KM, Dobek J, et al. Frailty in older breast cancer survivors: age, prevalence, and associated factors. Oncol Nurs Forum. May. 1. 2013;40(3):E126-34. [pmid: 23615146].
2 Campbell KL, Pusic AL, Zucker DS, et al. A prospective model of care for breast cancer rehabilitation: function. Cancer. Apr. 15. 2012;118(8 Suppl):2300-11. [pmid: 22488704].
3 Cheung WY, Neville BA, Earle CC. Associations among cancer survivorship discussions, patient and physician expectations, and receipt of follow-up care. J Clin Oncol. May. 20. 2010;28(15):2577-83. [pmid: 20406932].
4 Chubak J, Tuzzio L, Hsu C, et al. Providing Care for Cancer Survivors in Integrated Health Care Delivery Systems: Practices, Challenges, and Research Opportunities. J Oncol Prac. 2012;8(3):184-9.
5 Del Giudice EM, Paszat LF, Rabeneck L, et al. Long-term surveillance and preventive practices among healthy young adult cancer survivors. J Clin Oncol. 2011;29(15).
6 Del Giudice ME, Grunfeld E, Harvey BJ, et al. Primary care physicians' views of routine follow-up care of cancer survivors. J Clin Oncol. Jul. 10. 2009;27(20):3338-45. [pmid: 19380442].
7 Forsythe LP, Alfano CM, Leach CR, et al. Who provides psychosocial follow-up care for post-treatment cancer survivors? A survey of medical oncologists and primary care physicians. J Clin Oncol. Aug. 10. 2012;30(23):2897-905. [pmid: 22778322].
8 Grunfeld E, Gray A, Mant D, et al. Follow-up of breast cancer in primary care vs specialist care: results of an economic evaluation. Br J Cancer. Mar. 1999;79(7-8):1227-33. [pmid: 10098764].
9 Grunfeld E, Levine MN, Julian JA, et al. Randomized trial of long-term follow-up for early-stage breast cancer: a comparison of family physician versus specialist care. J Clin Oncol. Feb. 20. 2006;24(6):848-55. [pmid: 16418496].
10 Grunfeld E, Mant D, Yudkin P, et al. Routine follow up of breast cancer in primary care: randomised trial. BMJ. Sep. 14. 1996;313(7058):665-9. [pmid: 8811760].
11 Hershman DL, Greenlee H, Awad D, et al. Randomized controlled trial of a clinic-based survivorship intervention following adjuvant therapy in breast cancer survivors. Breast Cancer Res Treat. Apr. 2013;138(3):795-806. [pmid: 23542954].
12 Hong S, Nekhlyudov L, Didwania A, et al. Cancer survivorship care: exploring the role of the general internist. J Gen Intern Med. Nov. Suppl 2. 2009;24:S495-500. [pmid: 19838857].
13 Howell D, Hack TF, Oliver TK, et al. Models of care for post-treatment follow-up of adult cancer survivors: a systematic review and quality appraisal of the evidence. J Cancer Surviv. Dec. 2012;6(4):359-71. [pmid: 22777364].
14 Keegan TH, Lichtensztajn DY, Kato I, et al. Unmet adolescent and young adult cancer survivors information and service needs: a population-based cancer registry study. J Cancer Surviv. Sep. 2012;6(3):239-50. [pmid: 22457219].
15 Kent EE, Arora NK, Rowland JH, et al. Health information needs and health-related quality of life in a diverse population of long-term cancer survivors. Patient Educ Couns. Nov. 2012;89(2):345-52. [pmid: 23021856].
16 McCabe MS, Bhatia S, Oeffinger KC, et al. American Society of Clinical Oncology statement: achieving high-quality cancer survivorship care. J Clin Oncol. Feb. 10. 2013;31(5):631-40. [pmid: 23295805].
17 Nekhlyudov L, Schnipper JL. Cancer Survivorship Care Plans: What Can Be Learned From Hospital Discharge Summaries?. J Oncol Prac. 2012;8(1):24-9.
18 Silver JK, Baima J, Mayer RS. Impairment-driven cancer rehabilitation: An essential component of quality care and survivorship. CA Cancer J Clin. Sep. 2013;63(5):295-317. [pmid: 23856764].
19 Sisler JJ, Taylor-Brown J, Nugent Z, et al. Continuity of care of colorectal cancer survivors at the end of treatment: the oncology-primary care interface. J Cancer Surviv. Dec. 2012;6(4):468-75. [pmid: 23054849].
20 Smith AW, Reeve BB, Bellizzi KM, et al. Cancer, comorbidities, and health-related quality of life of older adults. Health Care Financ Rev. Summer. 2008;29(4):41-56. [pmid: 18773613].