# Sample Data Abstraction Forms

Title and Abstract Review Form

1. Does the manuscript describe a model or component(s) of a model(s) through an experimental study, observational study, systematic review or case series in English? If no, exclude (EXC1) for Wrong design. Articles excluded for this reason include but are not limited to nonsystematic review articles, opinions, commentaries, editorials /letters to the editor with no primary data and case reports and non-English. 2. If yes or cannot tell, does the manuscript describe a model or component(s) of a model(s) through an experimental study, observational study, systematic review or case series in English? If no, exclude (EXC2) for wrong or no intervention. Studies excluded for this reason include those focusing on topics other than survivorship care (e.g., intervention with curative intent, or no intervention for survivorship care).*Use this code only if EXC1 and EXC3 and do not fit. 3. If yes or cannot tell, does the study report on our population of interest: ages 19+ and survivor of any adult cancer that is currently in remission? If no, exclude (EXC3) – for wrong population. Studies excluded for this reason inbclude pediatric populations, adult survivors of childhood cancers, relapse patients and individuals with metastatic cancer. 4. If yes or cannot tell, does the manuscript report on a patient outcome related to the survivorship care model or any intermediate health outcome for GQ3? Ex: morbidity, mortality, quality of life, satisfaction with care, cost and resource utilization and adverse events? If no, exclude (EXC4) for wrong outcome. Studies excluded for this reason include outcomes that are attributable to the cancer treatment (not including adverse events and other latent cancer treatment effects) or only look at modifiers or predictors of study. *Use this code only if EXC1 and EXC3 and do not fit. 5. If yes, include! 6. Exclude (EXC 5) single service only interventions. For example, study is on survivorship care but include only one service within one of the four core IOM survivorship core components. (i.e. diet/nutrition or exercise program). 7. if no for any item above, is the article relevant for understanding survivorship care, the context, or future research directions GQ1, 2 OR 4? OR is the study in progress and should be revisited for results? If yes, include for background.

Full Text Review Form

1. Does the manuscript describe a model or component(s) of a model(s) through an experimental study, observational study, systematic review or case series in English? If no, exclude (EXC1) for Wrong design. Articles excluded for this reason include but are not limited to nonsystematic review articles, opinions, commentaries, editorials /letters to the editor with no primary data and case reports and non-English. 2. If yes or cannot tell, does the manuscript describe a model or component(s) of a model(s) through an experimental study, observational study, systematic review or case series in English? If no, exclude (EXC2) for wrong or no intervention. Studies excluded for this reason include those focusing on topics other than survivorship care (e.g., intervention with curative intent, or no intervention for survivorship care).*Use this code only if EXC1 and EXC3 and do not fit. 3. If yes or cannot tell, does the study report on our population of interest: ages 19+ and survivor of any adult cancer that is currently in remission? If no, exclude (EXC3) – for wrong population. Studies excluded for this reason inbclude pediatric populations, adult survivors of childhood cancers, relapse patients and individuals with metastatic cancer. 4. If yes or cannot tell, does the manuscript report on a patient outcome related to the survivorship care model or any intermediate health outcome for GQ3? Ex: morbidity, mortality, quality of life, satisfaction with care, cost and resource utilization and adverse events? If no, exclude (EXC4) for wrong outcome. Studies excluded for this reason include outcomes that are attributable to the cancer treatment (not including adverse events and other latent cancer treatment effects) or only look at modifiers or predictors of study. *Use this code only if EXC1 and EXC3 and do not fit. 5. If yes, include! 6. Exclude (EXC 5) single service only interventions. For example, study is on survivorship care but include only one service within one of the four core IOM survivorship core components. (i.e. diet/nutrition or exercise program). 7. if no for any item above, is the article relevant for understanding survivorship care, the context, or future research directions GQ1, 2 OR 4? OR is the study in progress and should be revisited for results? If yes, include for background.

Abstraction Form

1. Does the manuscript describe a model or component(s) of a model(s) through an experimental study, observational study, systematic review or case series in English? If no, exclude (EXC1) for Wrong design. Articles excluded for this reason include but are not limited to nonsystematic review articles, opinions, commentaries, editorials /letters to the editor with no primary data and case reports and non-English. 2. If yes or cannot tell, does the manuscript describe a model or component(s) of a model(s) through an experimental study, observational study, systematic review or case series in English? If no, exclude (EXC2) for wrong or no intervention. Studies excluded for this reason include those focusing on topics other than survivorship care (e.g., intervention with curative intent, or no intervention for survivorship care).*Use this code only if EXC1 and EXC3 and do not fit. 3. If yes or cannot tell, does the study report on our population of interest: ages 19+ and survivor of any adult cancer that is currently in remission? If no, exclude (EXC3) – for wrong population. Studies excluded for this reason inbclude pediatric populations, adult survivors of childhood cancers, relapse patients and individuals with metastatic cancer. 4. If yes or cannot tell, does the manuscript report on a patient outcome related to the survivorship care model or any intermediate health outcome for GQ3? Ex: morbidity, mortality, quality of life, satisfaction with care, cost and resource utilization and adverse events? If no, exclude (EXC4) for wrong outcome. Studies excluded for this reason include outcomes that are attributable to the cancer treatment (not including adverse events and other latent cancer treatment effects) or only look at modifiers or predictors of study. *Use this code only if EXC1 and EXC3 and do not fit. 5. If yes, include! 6. Exclude (EXC 5) single service only interventions. For example, study is on survivorship care but include only one service within one of the four core IOM survivorship core components. (i.e. diet/nutrition or exercise program). 7. if no for any item above, is the article relevant for understanding survivorship care, the context, or future research directions GQ1, 2 OR 4? OR is the study in progress and should be revisited for results? If yes, include for background.