# Key Informant Interview Methodology, Guiding Questions, Search Terms, and Gray Literature Methodology

We adhered to the Office of Management and Budget (OMB) requirements and limited standardized questions (the list of Guiding Questions [GQs]) to no more than nine nongovernment-associated individuals. As a result, we did not need to obtain OMB clearance for the interviews.

After review and approval of the completed Disclosure of Interest forms for the proposed Key Informants (KIs) by the Agency for Healthcare and Quality (AHRQ), over a 3-week period, we conducted interviews with 10 selected KIs, 2 of whom were government-associated individuals and did not count toward the OMB limit of 9 individuals who could be interviewed without clearance. The interviews were a combination of individual KIs and groups of KIs based on availability and concordance of perspectives. A co-investigator from the Evidence-based Practice Center (EPC) team led each of the KI interviews, and the Task Order Officer (TOO) was in attendance for all of the interviews along with other EPC team members. The recorded KI interviews ranged in duration from 0.5 hours to 1.5 hours. Following each interview, we summarized the interviews in writing by incorporating summary notes prepared by team members; interview recordings; and, for some, a professional transcription of the interview. We then submitted notes to the TOO for documentation. Using NVivo® qualitative software (v9.0), we coded the KIs' responses by relevant GQs and subquestions and generated summary reports by subquestion for analysis by the authors. Authors evaluated summary reports, corrected or added codes by referring to the original summary notes, and identified key themes from multiple perspectives. In addition, authors also identified unique perspectives from KIs.

We modified the order of the GQs to better align the topical content under the GQ domain. For instance, in KI interviews conducted for this project (described below), rather than initiating the interview with a question about models of care that have been widely used, we asked KIs to first describe usual care for survivors and then describe models of care. We also rephrased some of the questions to better clarify the intent of the question to facilitate KI discussions. For example, we combined two questions focusing on gaps in knowledge holding back the diffusion of survivorship care and new research necessary to reduce uncertainty in decisionmaking by asking, “Are gaps in knowledge holding back the diffusion of survivorship care? What are the most important knowledge gaps to fill through new research to reduce uncertainty in decisions?”

1. Guiding Question 1: Overview of cancer survivorship care
  - Is it possible to generalize “usual care” for cancer survivors in the United States? If so, how would you describe the nature of usual care for survivors of cancer? If not, can you describe some of the most common care practices?
  - How would you define a “model” of survivorship care as opposed to separate health care services that may be offered to cancer survivors? Are there specific components of care that need to be present for services to be considered a model?
  - What different models of cancer survivorship care have been most widely used? [For all KIs except for Research: What is your current or past experience with using different models of care?]
  - What are the advantages and disadvantages of these models, compared with one another and with usual care?
  - How widely is survivorship care offered? For how long?
  - Are there any potential safety issues and harms resulting from care provided in the models? If so, what are they?
2. Guiding Question 2: Context in which cancer survivorship care is used
  - Do patients and clinical care providers choose among survivorship care programs? If so, how do they decide among programs? If not, why not? Are providers generally aware of (or affiliated with) only a single program, or are patients generally informed of more than one option for survivorship care?
  - How do models of care vary based on
    ○ setting,
    ○ organizational structure,
    ○ provider type (including in the context of transitions of care),
    ○ payment considerations, and
    ○ patient characteristics such as age, race, cancer type, stage of disease, other risk stratification issues?
  - What associated supportive care resources are commonly incorporated in survivorship care programs? What supportive care resources that are not present are needed? (PROBE: Supportive care for caregivers/family of patient, or social support as a supportive care resource? Or both?)
  - How is (or could) risk stratification (be) applied to cancer survivor programs? [For patient advocates only: If patients who are considered at higher risk for problems, that is, late effects, are there programs or resources that can address those specific needs?)
  - What kinds of resources (e.g., health information technology) are available or needed to share information among health care providers and with cancer survivors?
  - What are important considerations for evaluating appropriate resource utilization, cost, quality of care, and outcomes for survivorship programs? [When you are considering your quality of care or minimizing costs what factors are important to weigh?]
  - What kinds of training and certification are required for providers involved in survivorship programs? What modifications to current training, certification, and staffing are in development?
3. Guiding Question 3: Current evidence
  - Do you have any information that may be useful to us in our evaluation of the current evidence?
4. Guiding Question 4: Gaps in knowledge and future research needs
  - Are gaps in knowledge holding back the diffusion of survivorship care? [could suggest other gaps such as reimbursement or other factors, if prompted by interviewee]
  - What are the most important knowledge gaps to fill through new research to reduce uncertainty in decisions?
  - Are any models of survivorship care planned but not yet implemented?
  - What are the differences between existing models of survivorship care and new and emerging models of survivorship care?
  - What are possible areas of future research?

Pub Med Search Terms (March 2013)

Search #1 | Query | Items found
#9 | Search “Survivors”[Mesh] OR survivorship OR survivor Filters: Humans; English | 498,795
#10 | Search “Neoplasms”[Mesh] Filters: Humans; English | 1,609,728
#11 | Search ((“Aftercare”[Mesh]) OR “Continuity of Patient Care”[Mesh]) OR “Delivery of Health Care”[Mesh] Filters: Humans; English | 586,760
#12 | Search ((“Patient Care Planning”[Mesh]) OR “Models, Nursing”[Mesh]) OR “Health Services/utilization”[Mesh]) OR “methods” [Subheading]) OR “standards” [Subheading] Filters: Humans; English | 1,801,900
#13 | Search (#9 AND #10 And #11 and #12) Filters: Humans; English | 1,575
#14 | Search (#9 AND #10 And #11 and #12) Filters: Humans; English; Adult: 19+ years | 972
#17 | Search (#9 AND #10 And #11 and #12) Filters: Editorial; Comment; Case Reports; Humans; English; Adult: 19+ years | 38
#19 | Search (#14 NOT #17) | 934
Search #2 | Query | Items found
#1 | Search 23257892[uid] | 1
#2 | Search “Survivors”[Mesh] OR survivorship OR survivor | 771,137
#3 | Search “Neoplasms”[Mesh] | 2,411,985
#4 | Search ((“Aftercare”[Mesh]) OR “Continuity of Patient Care”[Mesh]) OR “Delivery of Health Care”[Mesh] | 744,808
#5 | Search ((((“Patient Care Planning”[Mesh]) OR “Models, Nursing”[Mesh]) OR “Health Services/utilization”[Mesh]) OR “methods” [Subheading]) OR “standards” [Subheading] | 2,854,158
#6 | Search (#2 AND #3 and #4 AND #5) | 1,715
#7 | Search (#2 AND #3 and #4 AND #5) Filters: Humans | 1,712
#8 | Search (#2 AND #3 and #4 AND #5) Filters: Humans; Adult: 19+ years | 1,020
#9 | Search (#2 AND #3 and #4 AND #5) Filters: Humans; English; Adult: 19+ years | 975
#10 | Search (#1 AND #9) Filters: Humans; English; Adult: 19+ years | 0
#11 | Search (#1 AND #9) Schema: all Filters: Humans; English; Adult: 19+ years | 0
#12 | Search (#1 AND #9) | 0
#13 | Search (#1 AND #9) Schema: all | 0
#14 | Search ((“Survivors”[MAJR] AND “Neoplasms/therapy”[MAJR])) AND (“Aftercare”[Majr] AND “Delivery of Health Care”[Mesh]) | 30
#15 | Search (#14 AND #1) | 1
#16 | Search (#14 NOT #9) | 19

PubMed = 953 non duplicated results

Pub Med Update Search (August 2013)

Search #3 | Query | Items found
#1 | Search “Survivors”[Mesh] OR survivorship OR survivor | 797912
#2 | Search “Neoplasms”[Mesh] | 2457689
#3 | Search ((“Aftercare”[Mesh]) OR “Continuity of Patient Care”[Mesh]) OR “Delivery of Health Care”[Mesh] | 761518
#4 | Search (((((“Patient Care Planning”[Mesh]) OR “Models, Nursing”[Mesh]) OR “Health Services/utilization”[Mesh]) OR “methods” [Subheading]) OR “standards” [Subheading] | 2935558
#5 | Search (#1 AND #2 AND #3 AND #4) | 1810
#6 | Search (#1 AND #2 AND #3 AND #4) Filters: Editorial | 37
#7 | Search (#1 AND #2 AND #3 AND #4) Filters: Editorial; Comment | 69
#8 | Search (#1 AND #2 AND #3 AND #4) Filters: Editorial; Comment; Case Reports | 102
#9 | Search (#5 NOT #8) | 1708
#10 | Search (#5 NOT #8) Filters: Humans | 1705
#11 | Search (#5 NOT #8) Filters: Humans; English | 1575
#12 | Search (#5 NOT #8) Filters: Humans; English; Adult: 19+ years | 999
#13 | Search (“2013”[Date - Entrez] : “3000”[Date - Entrez]) Filters: Humans; English; Adult: 19+ years | 29790
#14 | Search (#12 AND #13) Filters: Humans; English; Adult: 19+ years | 19
#15 | Search ((“Survivors”[MAJR] AND “Neoplasms/therapy”[MAJR])) AND (“Aftercare”[Majr] AND “Delivery of Health Care”[Mesh]) Filters: Humans; English; Adult: 19+ years | 19
#16 | Search (#13 AND #15) Filters: Humans; English; Adult: 19+ years | 0
#17 | Search (#13 AND #15) Schema: all Filters: Humans; English; Adult: 19+ years | 0

Pub Med Search Terms (August 2013)

PubMed = 17 non duplicated results

## Gray Literature Search

GQs 1 and 2 relied primarily on information from published narrative reviews and information in the gray literature. Sources for the gray literature included the following:

- LexisNexis® Academic: This source provides mostly full-text access to general, regional, and international news; company news and financial information; legal information (including law reviews, case law, and legal rulings); and other topics such as biographical information. LexisNexis Academic is a Web-based service that provides access to most of the information formerly available on the LexisNexis® Educational Program (approximately 75 percent of the titles).
- ProQuest Dissertations & Theses: This source indexes U.S. dissertations from 1861 to as recently as the last semester with full text available from 1997 on. Master's theses are covered more selectively and some full text is available. The database covers work done at more than a thousand institutions, primarily in the United States but also in Canada and Great Britain, and at other European universities for recent years. In addition to this database, the full text of most of the theses and dissertations completed at the University of North Carolina at Chapel Hill (UNC) from 2006, and all beginning in 2008, are freely available electronically from the UNC Health Sciences Library.
- NIH RePORTER database: The information found in RePORTER is drawn from several extant databases (eRA databases, MEDLINE®, PubMed® Central, the NIH Intramural Database, and iEdison), using newly formed linkages among these disparate data sources. The comprehensiveness of these databases varies, as does the quality of the linkages formed among them. We expect that the quality of RePORTER data will improve over time as a result of changes in both data collection (e.g., implementation of the NIH Public Access policy) and the increased ability to identify missing information that comes from making these data accessible to more people.
- HSRProj (Health Services Research Projects in Progress): HSRProj contains descriptions of research in progress funded by Federal and private grants and contracts for use by policymakers, managers, clinicians, providers, and other decisionmakers. It provides access to information about health services research in progress before results are available in a published form.

We included a Web site search of relevant organizations such as the American Society of Clinical Oncology, the American Cancer Society, and the National Coalition for Cancer Survivorship. We used the gray literature to search for additional model components that are in piloting stages or not yet fully implemented.