# Summary and Implications

## Guiding Question 4 What important issues are raised by using GEP testing for stage II colon cancer?

Colon cancer is a common malignancy in both women and men. Improving the decisionmaking about adjuvant chemotherapy for patients with stage II, that is, node-negative, colon cancer is an important clinical question. The majority of stage II patients do well with surgery alone, but some patients do develop recurrent disease and show improved survival from adjuvant chemotherapy. Gene expression profile (GEP) assays are one potential novel approach to determine risk of recurrence and benefit of adjuvant therapy and thus improve this decisionmaking by either avoiding chemotherapy and medication-related adverse effects in those unlikely to have a recurrence or identifying those most likely to show benefit from adjuvant chemotherapy.

However, in order to assure that use of GEP assays improves clinical care of patients, the GEP assays need to demonstrate clinical validity and clinical utility. Clinical validity is necessary but not sufficient; it demonstrates the relationship between the GEP result and clinical outcome in a population. Clinical utility is evidence that use of the GEP assay improves net health outcome.

### What Are the Key Unresolved or Controversial Issues With Using GEP Testing in Patients With Stage II Colon Cancer?

While the potential advantages of using the GEP assays seem promising, the clinical utility is uncertain. No prospective studies have reported on what happens to net health outcome, considering both benefits and harms, when GEP results are used in managing patients. Data are also very limited for net reclassification analysis; that is, how the overall risk classification provided by GEP results compares with risk classification using other predictors. Reclassification analysis might be used in assessing clinical utility by analyzing how the changes in patient classifications impact net health outcome.

For some GEP assays, there is also uncertainty about the clinical validity, that is, the initial results have not been evaluated (validated) using a large number of samples from different representative populations. Also, most of the studies have evaluated the GEP assays as a possible prognostic marker for disease recurrence. There is much less information regarding use as a predictive marker for response to adjuvant chemotherapy, which would impact patient management. To date, information is lacking about the extent to which GEP results do, or do not, classify patients into distinct groups that have clinical relevance.

Indications for use of the GEP assay have not been defined. Which patients with stage II colon cancer will be tested is an open question: will the GEP be used with all stage II patients or just those with T3 tumors that are microsatellite stable (do not have microsatellite instability) or some other subgroup of patients? Another concern is that there is little information about reproducibility of the GEP test results. Test variability can result from different approaches to sample preparation, analysis, and perhaps heterogeneity of the tumor. In addition, factors such as tissue ischemia at surgery, use of certain medications, and nutrition that have been noted to impact gene expression need consideration.

The publications describing GEP assays also varied considerably in methods and definition. For example, recurrence was sometimes considered only as cancer metastatic to liver or lung while in other cases local recurrence was also included. The rigor with which recurrence was defined and verified also varied among studies. This topic needs more attention in future studies. The impact of surgical technique was given some consideration, but could have further implications. In stage II patients, an indeterminate or positive resection margin is a clinical marker for high risk of recurrence. So, one could assume that the results of a GEP assay would not predict future events related to the surgical procedure, for example, a recurrence related to a resection margin that showed cancer cells. An inadequate number of assessed lymph nodes (12 or fewer) is also a marker for high-risk patients, likely because some of these patients have stage III disease (positive lymph nodes). Inadequate assessment can occur because of either incomplete sampling at surgery or incomplete pathological evaluation. Adequate lymph node sampling (sampling and reporting) is now recognized as an important quality measure in colon cancer surgery. However, in older series inadequate assessment occurred more often. Thus, GEP assays derived from these older series may not apply to current patients where sufficient numbers of nodes are typically obtained and analyzed. Thus, it is important to note the adequacy of lymph node assessment for both studies of GEP derivation and validation. One important aspect of the outcome of recurrence that was not found to be problematic was duration of followup; this was typically assessed with a minimum followup of 3 years.

While at the time of this report there are five commercially available GEP assays, this is an area of active research and it seems likely that additional assays will become available in the next 1 to 2 years. Currently available GEP assays are being marketed as laboratory-developed tests (LDT); currently, none of the commercially available GEP assays has specific FDA approval for use in stage II colon cancer.

### What are the Implications of the Current Level of Diffusion and/or Further Diffusion of This Technology/Intervention Given the Current State of the Evidence?

While results of both false-positive and false-negative tests raise concerns, incorrectly identifying someone as low-risk with the GEP result and not administering adjuvant chemotherapy, especially in a patient with clinical risk factors, may lead to significant consequences. Thus, the performance of these assays needs to be evaluated in multiple patients from diverse settings. While there is some use of these tests at present, given the major unanswered questions noted above, further diffusion of GEP in making treatment-related decisions, such as not giving adjuvant chemotherapy, raises concern. In addition, the lack of data related to GEP assays for predicting improved survival with adjuvant chemotherapy is also of concern.

While specific rates of use for the commercially available GEP assays are not known, our Key Informants felt there is limited current use of GEP assays in the care of patients with stage II colon cancer based on their clinical experience and/or discussions with colleagues. While Key Informants agreed this was both an important clinical issue and an active research question, they differed in their opinions about future trends in use of the GEP assays in light of the current evidence. Key Informants noted that additional information related to clinical utility, such as prospective trials and/or net reclassification analysis, was needed.

Since only a few of the GEP tests that have been reported in the literature are available commercially, the state of the evidence for commercially available GEP assays is presented in Table 10. This table does not compare results for each of the assays nor comment on the quality of the studies; this table only indicates whether or not a type of evidence is available, including whether or not there has been successful validation of the GEP assay, in the peer-reviewed literature. Additional information about each of these assays, including more detail about individual studies, is presented in Table 3 and Table 4.

Table 10 Summary of peer-reviewed studies for available gene expression assays for use in the decision about adjuvant chemotherapy in stage II colon cancer

Assay | Validated for Recurrence (Stage II) | Validated for Treatment Benefit | Net Reclassification Analysis | Clinical Utility
ColoPrint^®^* | Yes | No | For derivation study only | No
ColonPRS^®^+ | Yes | No | No | No
GeneFx^®^ Colon | Yes | No | No | No
OncoDefender-CRC | No, Combined validation for stage I/II colon cancer | No | No | No
Oncotype DX^®^ Colon Cancer Assay | Yes | No | No | No

* May also be available for use through PARSC Clinical Trial

+ Currently (July 2012) available for nondiagnostic or research use only

As shown in the Evidence Map section of this Brief and Table 10, the clinical utility for use of GEP assays is not known. We did not identify any prospective studies that assessed change in net health outcome with use of a GEP assay, nor did we identify studies that used an overall reclassification analysis and analyzed the impact of the reclassification from use of a GEP assay on net health outcome as an approach to assess clinical utility. There also was limited information on the reproducibility of test findings. It also is not certain which stage II patients, all or a subset, might be tested using the GEP assay. The publications also do not discuss whether or not results of the GEP assays stratify patients into clinically meaningful groups. As noted above in Table 9, trials are in progress but they may not address or provide results for all the major issues noted in this section. The PARSC study using the ColoPrint^®^ assay appears designed to answer a number of key questions for this one assay. Box 1 summarizes the key decisionmaking uncertainties we identified for use of GEP assays in stage II colon cancer.

Box 1 Key decisionmaking uncertainties for gene expression profiling assays in stage II colon cancer

##### Analytic Validity

- What is the reproducibility of the assay results?
- Is there an effect of sample preparation, analysis, and/or tumor heterogeneity?

##### Clinical Validity (Diagnostic Accuracy)

- How is recurrence defined, e.g. local disease, distant disease, or both?
- Are prognostic (recurrence) and/or predictive (benefit from therapy) uses considered?
- How extensively has the gene expression profiling (GEP) assay been tested (validated) with additional patients from different populations?

##### Patients

- Which patients (which subsets) with stage II colon cancer should receive GEP testing?
- Might this only be used in T3 tumors with without microsatellite instability?

##### Clinical Utility

- What is the clinical utility for use of the GEP results?
- How does use impact net outcome, such as survival or recurrence-free survival?
  - This can be measured through prospective studies.
  - Reclassification analysis (net reclassification) linked with change in net health outcome might also provide information.
- How does use of GEP compare with other approaches to risk stratification (classification)?

## Next Steps

### Conceptual Framework and Future Research

In this Technical Brief we have organized the emerging gene expression profile (GEP) tests according to their unique signatures and have also noted which GEP assays are commercially available. Regardless of specific aspects of a GEP assay, the assessment of diagnostic tests typically follows a stepwise approach.47 This approach progresses from establishing the technical (analytic) and clinical validity to assessing the impact of the test result on clinical decisionmaking and then patient outcome. The potential adverse effects from use of the test are also considered. This step-wise approach is applicable to use of GEP testing in stage II colon cancer (Figure 1).

Figure 1 Analytic Framework

Figure 1 is a depiction of the analytic framework, that is, a graph that depicts five research questions. Research question 1 (test accuracy) shows the link between patients with stage II colon cancer for whom adjuvant therapy is being considered and patient classification with respect to tumor recurrence or benefit from adjuvant therapy. Research question 2 (impact of test on management) shows the link between patient classification (result of GEP assay) and the changes in clinical decisionmaking regarding adjuvant therapy. Research question 3 (impact of management on health outcomes) shows the link between the clinical impact of the treatment decision and the outcomes of survival and recurrence. Research question 4 (adverse effects of test-directed treatment) considers the link betwen test-directed treatment and adverse events, and research question 5 (adverse effects of testing) considers the link between testing and adverse events.

#### What Are the Important Questions for Future Research?

Based on this conceptual framework, findings from the evidence map, and input from Key Informants, we suggest that future research on the various GEP assays, whether used for prognostic or predictive measures, include the following:

- Clinical Utility. Does use of the GEP assay for treatment management improve net health outcome (considering benefits and risks) in patients with stage II colon cancer? (Research questions 2, 3, 4, and 5). Studies should be prospective trials using GEP results or the studies should compare classification with use of GEP results to results with use of conventional risk stratification and link the changes in classification to their impact on net health outcome. Can prognostic GEP assays identify individual patients at low risk of recurrence who can safely avoid adjuvant chemotherapy? Can GEP assays identify individual patients who will show improved survival with adjuvant chemotherapy or particular adjuvant regimens?
- Clinical Validity. How strongly is the GEP assay result correlated with the outcome of interest? Development of evidence on clinical utility requires robust evidence on clinical validity. (Research question 1).
- Patients. Which patients with stage II colon cancer should be tested using the GEP assay? (Research question 2). Should the GEP test is applied to all stage II colon cancer patients or a subset such as those whose tumors do not have microsatellite instability?
- What is the analytic validity of the GEP assay? (Research question 1). Are results reproducible?

While information is emerging about use of GEP assays to inform the decision about use of adjuvant chemotherapy in stage II colon cancer, studies to date have not provided the type of information needed to address major uncertainties.