# References

1 Siegel R, Naishadham D, Jemal A. Cancer statistics, 2012. CA Cancer J Clin. Jan–Feb. 2012;62(1):10-29. [pmid: 22237781].
2 Libutti SK, Saltz LB, Willett CG. Cancer of the colon. Devita VT, Lawrence TS, Rosenberg SA, editors. Cancer: Principles & Practice of Oncology. 9th ed. Philadelphia. Lippincott Williams & Wilkins. 2011:1099.
3 Edge SB, Byrd DR, Compton CC, et al. AJCC Cancer Staging Manual. New York, NY. Springer. 2010.
4 Gunderson LL, Jessup JM, Sargent DJ, et al. Revised TN categorization for colon cancer based on national survival outcomes data. J Clin Oncol. Jan. 10. 2010;28(2):264-71. [pmid: 19949014].
5 Network NCC. Colon Cancer. 2012. www.nccn.org/professionals/physician_gls/f_guidelines.asp. Accessed on Version 3.
6 Midgley R, Rasul K, Al Salama H, et al. Gene profiling in early stage disease. Cancer J. May–Jun. 2010;16(3):210-3. [pmid: 20526098].
7 Lu AT, Salpeter SR, Reeve AE, et al. Gene expression profiles as predictors of poor outcomes in stage II colorectal cancer: A systematic review and meta-analysis. Clin Colorectal Cancer. Oct. 2009;8(4):207-14. [pmid: 19822511].
8 Vilar E, Gruber SB. Microsatellite instability in colorectal cancer-the stable evidence. Nat Rev Clin Oncol. Mar. 2010;7(3):153-62. [pmid: 20142816].
9 Tabernero J, Baselga J. Multigene assays to improve assessment of recurrence risk and benefit from chemotherapy in early-stage colon cancer: has the time finally arrived, or are we still stage locked?. Journal of Clinical Oncology. Sep. 1. 2010;28(25):3904-7. [pmid: 20679612].
10 Gerlinger M, Rowan AJ, Horswell S, et al. Intratumor heterogeneity and branched evolution revealed by multiregion sequencing. N Engl J Med. Mar. 8. 2012;366(10):883-92. [pmid: 22397650].
11 Marchionni L, Wilson RF, Marinopoulos SS, et al. Impact of Gene Expression Profiling Tests on Breast Cancer Outcomes. (The Johns Hopkins University Evidence-based Practice Center, Baltimore, MD). Rockville, MD. Agency for Healthcare Research and Quality. 2008. www.ahrq.gov/downloads/pub/evidence/pdf/brcancergene/brcangene.pdf.
12 Hayes DF, Bast RC, Desch CE, et al. Tumor marker utility grading system: a framework to evaluate clinical utility of tumor markers. J Natl Cancer Inst. Oct. 16. 1996;88(20):1456-66. [pmid: 8841020].
13 Simon RM, Paik S, Hayes DF. Use of archived specimens in evaluation of prognostic and predictive biomarkers. J Natl Cancer Inst. Nov. 4. 2009;101(21):1446-52. [pmid: 19815849].
14 United States Food and Drug Administration. www.fda.gov.
15 Benson AB 3rd, Schrag D, Somerfield MR, et al. American Society of Clinical Oncology recommendations on adjuvant chemotherapy for stage II colon cancer. J Clin Oncol. Aug. 15. 2004;22(16):3408-19. [pmid: 15199089].
16 Barrier A. Stage II colon cancer prognosis prediction by tumor gene expression profiling. J Clin Oncol. 2006;24(29):4685-91. [pmid: 16966692].
17 Barrier A, Roser F, Boelle PY, et al. Prognosis of stage II colon cancer by non-neoplastic mucosa gene expression profiling. Oncogene. Apr. 19. 2007;26(18):2642-8. [pmid: 17043639].
18 Blum C, Graham A, Yousefzadeh M, et al. The expression ratio of Map7/B2M is prognostic for survival in patients with stage II colon cancer. Int J Oncol. September. 2008;33(3):579-84. [pmid: 18695889].
19 Eschrich S, Yang I, Bloom G, et al. Molecular staging for survival prediction of colorectal cancer patients. Journal of Clinical Oncology. May. 20. 2005;23(15):3526-35. [pmid: 15908663].
20 Gray RG, Quirke P, Handley K, et al. Validation study of a quantitative multigene reverse transcriptase-polymerase chain reaction assay for assessment of recurrence risk in patients with stage II colon cancer. J Clin Oncol. Dec. 10. 2011;29(35):4611-9. [pmid: 22067390].
21 Grone J, Lenze D, Jurinovic V, et al. Molecular profiles and clinical outcome of stage UICC II colon cancer patients. Int J Colorectal Dis. Jul. 2011;26(7):847-58. [pmid: 21465190].
22 Hong Y, Downey T, Eu KW, et al. A ‘metastasis-prone’ signature for early-stage mismatch-repair proficient sporadic colorectal cancer patients and its implications for possible therapeutics. Clin Exp Metastasis. Feb. 2010;27(2):83-90. [pmid: 20143136].
23 Kennedy RD, Bylesjo M, Kerr P, et al. Development and independent validation of a prognostic assay for stage II colon cancer using formalin-fixed paraffin-embedded tissue. J Clin Oncol. Dec. 10. 2011;29(35):4620-6. [pmid: 22067406].
24 Lenehan PF, Boardman LA, Riegert-Johnson D, et al. Generation and external validation of a tumor-derived 5-gene prognostic signature for recurrence of lymph node-negative, invasive colorectal carcinoma. Cancer. 2012. May. 17. [pmid: 22605513].
25 Mettu RK, Wan YW, Habermann JK, et al. A 12-gene genomic instability signature predicts clinical outcomes in multiple cancer types. Int J Biol Markers. Oct–Dec. 2010;25(4):219-28. [pmid: 21161944].
26 Nitsche U, Maak M, Schuster T, et al. ColoPrint® – ein vielversprechender Gentest zur Risikoabschätzung bei Patienten mit Kolonkarzinom. Journal Onkologie. 2012:454-6. (English language abstract).
27 O’Connell MJ, Lavery I, Yothers G, et al. Relationship between tumor gene expression and recurrence in four independent studies of patients with stage II/III colon cancer treated with surgery alone or surgery plus adjuvant fluorouracil plus leucovorin. J Clin Oncol. Sep. 1. 2010;28(25):3937-44. [pmid: 20679606].
28 Salazar R, Roepman P, Capella G, et al. Gene expression signature to improve prognosis prediction of stage II and III colorectal cancer. J Clin Oncol. Jan. 1. 2011;29(1):17-24. [pmid: 21098318].
29 Schepeler T, Reinert JT, Ostenfeld MS, et al. Diagnostic and prognostic microRNAs in stage II colon cancer. Cancer Res. Aug. 1. 2008;68(15):6416-24. [pmid: 18676867].
30 Smith JJ, Deane NG, Wu F, et al. Experimentally derived metastasis gene expression profile predicts recurrence and death in patients with colon cancer. Gastroenterology. Mar. 2010;138(3):958-68. [pmid: 19914252].
31 Van Laar RK. An online gene expression assay for determining adjuvant therapy eligibility in patients with stage 2 or 3 colon cancer. Br J Cancer. Dec. 7. 2010;103(12):1852-7. [pmid: 21119668].
32 Wan YW, Qian Y, Rathnagiriswaran S, et al. A breast cancer prognostic signature predicts clinical outcomes in multiple tumor types. Oncol Rep. Aug. 2010;24(2):489-94. [pmid: 20596637].
33 Wang Y, Jatkoe T, Zhang Y, et al. Gene expression profiles and molecular markers to predict recurrence of Dukes’ B colon cancer. J Clin Oncol. May. 1. 2004;22(9):1564-71. [pmid: 15051756].
34 Jorissen RN, Gibbs P, Christie M, et al. Metastasis-Associated Gene Expression Changes Predict Poor Outcomes in Patients with Dukes Stage B and C Colorectal Cancer. Clin Cancer Res. Dec. 15. 2009;15(24):7642-51. [pmid: 19996206].
35 Thorsteinsson M, Kirkeby LT, Hansen R, et al. Gene expression profiles in stages II and III colon cancers: application of a 128-gene signature. Int J Colorectal Dis. 2012. Jun. 19. [pmid: 22710688].
36 Clark-Langone KM, Sangli C, Krishnakumar J, et al. Translating tumor biology into personalized treatment planning: analytical performance characteristics of the Oncotype DX Colon Cancer Assay. BMC Cancer. 2010;10:691. [pmid: 21176237].
37 Adams H, Hinzmann B, Mayr T, et al. Predictor c: A tissue-based IVD predicting progression of disease in colorectal cancer UICC stages II or III. J Clin Oncol. 2010;28(15 SUPPL 1):3612.
38 Venook AP, Niedzwiecki D, Lopatin M, et al. Validation of a 12-gene colon cancer recurrence score (RS) in patients (pts) with stage II colon cancer (CC) from CALGB 9581. J Clin Oncol. 2011;29:2518.
39 Cartwright TH, Chao C, Lopatin M, et al. Effect of Oncotype DX colon cancer test results on treatment recommendations in patients with stage II colon cancer: Preliminary results. J Clin Oncol. 2012;30(suppl 4):abstr 398.
40 Tabernero J, Moreno V, Rosenberg R, et al. Clinical and technical validation of a genomic classifier (ColoPrint) for predicting outcome of patients with stage II colon cancer. J Clin Oncol. 2012;30(suppl 4):abstr 384.
41 O’Connell M, Lee M, Lopatin M, et al. Validation of the 12-gene colon cancer recurrence score (RS) in NSABP C07 as a predictor of recurrence in stage II and III colon cancer patients treated with 5FU/LV (FU) and 5FU/LV+oxaliplatin (FU+Ox). ASCO Meeting Abstracts. May. 30. 2012;30(15_suppl):3512.
42 Roth A. Lessons from PETACC3 in adjuvant treatment of colorectal cancer: Today’s impact. Eur J Cancer. March. 2012;48:S3.
43 Budinska E, Popovici VC, Sikora KO, et al. Identification and validation of gene expression subtypes in a large set of colorectal cancer samples. ASCO Meeting Abstracts. May. 30. 2012;30(15_suppl):3511.
44 Mambo E, Sanford T, Buddavarapu K, et al. Evaluation of the prognostic utility of miRNA and multiple genetic markers in stage IIA colon cancer. ASCO Meeting Abstracts. May. 30. 2012;30(15_suppl):3630.
45 Salazar R, Tabernero J, Moreno V, et al. Validation of a genomic classifier (ColoPrint) for predicting outcome in the T3-MSS subgroup of stage II colon cancer patients. ASCO Meeting Abstracts. May. 30. 2012;30(15_suppl):3510.
46 Salazar R, Marshall J, Capdevila J, et al. The PARSC trial, a prospective study for the assessment of recurrence risk in stage II colon cancer patients using ColoPrint. ASCO Meeting Abstracts. May. 30. 2012;30(15_suppl):TPS10632.
47 Lijmer JG, Leeflang M, Bossuyt PM. Proposals for a phased evaluation of medical tests. Med Decis Making. Sep–Oct. 2009;29(5):E13-21. [pmid: 19605881].
48 Lesko LJ, Atkinson AJ Jr. Use of biomarkers and surrogate endpoints in drug development and regulatory decision making: criteria, validation, strategies. Annu Rev Pharmacol Toxicol. 2001;41:347-66. [pmid: 11264461].
49 Subramanian J, Simon R. What should physicians look for in evaluating prognostic gene-expression signatures?. Nature Reviews Clinical Oncology. Jun. 2010;7(6):327-34. [pmid: 20421890].
50 Centers for Disease Control and Prevention. ACCE Model Process for Evaluating Genetic Tests. Atlanta, GA. Centers for Disease Control and Prevention. 2010. www.cdc.gov/genomics/gtesting/ACCE/. Accessed on February 15, 2012.