# Methods

Several sources were used to inform this Technical Brief. Information was collected from a review of published medical literature, narrative review articles, a search of the grey literature, and discussions with Key Informants. In addition, the Agency for Healthcare Research and Quality’s (AHRQ’s) Scientific Resource Center requested Scientific Information Packets from test manufacturers in March and April 2012.

Guiding Questions 1 and 2 above rely on information from published narrative reviews and clinical guidelines and information in the grey literature. The latter included information culled from manufacturers, patient advocacy groups, and other sources as identified in an Internet search (described in the following sections).

Guiding Question 3 was addressed through a review of the peer-reviewed literature. Key Informants provided input on the potential clinical outcomes of interest and the potential benefits and harms of GEP testing.

Guiding Question 4 relies on integrating information from Key Informants, grey literature, narrative reviews, and review of the literature.

Given the current role of GEP testing in patients with breast cancer, questions formulated in a report for the AHRQ on GEP testing in patients with breast cancer11 were used to inform this Technical Brief. In developing the framework for review of the published literature, this Brief used prior publications that discussed approaches for use of archived specimens and assessment of tumor-marker utility.12, 13

## Data Sources

### Discussions With Key Informants

The Key Informants included clinical experts, payers, and patients. The clinical experts were from the disciplines of medical oncology, surgical oncology, laboratory medicine, epidemiology, and clinical genetics and had expertise in colon cancer and/or genetics.

One group conference call was held with the Key Informants. During the first call, the Key Informants provided input on the literature review, for example, key outcomes, potential tests, and proposed inclusion/exclusion criteria for the literature search. As followup to the group conference call, the Key Informants were interviewed individually by telephone, using a semi-structured interview outline that provided the content experts the opportunity to share their experiences with GEP testing in patients with colon cancer and their opinions on unresolved or controversial issues related to GEP testing.

### Grey Literature Search

Internet search was conducted at the FDA Web site concerning GEP tests in stage II colon cancer. Additional searches were conducted as noted below. This information was used in answering Guiding Questions 1, 2, and 4.

Web sites of companies who are developing and currently offering GEP tests for colon cancer were searched to inform Guiding Questions 1 and 2. Examples include Agendia, Inc. (www.agendia.com/pages/coloprint/), Precision Therapeutics (www.precisiontherapeutics.com), Everist genomics (www.everistgenomics.com), Genomic Health (www genomichealth.com), Signal Genetics, LLC (www.signalgenetics.com and https://www.chipdx.com/colon-module.aspx), Signature Diagnostics (www.signature-diagnostics.de/predictor.htm), and Affymetrix, Inc. (www.affymetrix.com).

Clinical guidelines for colon cancer were reviewed for recommendations on using GEP testing for stage II colon cancer. Guidelines reviewed were from the American Society of Clinical Oncology (www.asco.org and www.cancer.net) and the National Comprehensive Cancer Network (www.nccn.org).

Patient-oriented and patient-advocacy Web sites for colon cancer were searched. Sites reviewed included the American Cancer Society (www.cancer.org), American Society of Clinical Oncology (www.asco.org), CancerColon Cancer Alliance (www.ccalliance.org), Fight Colorectal Cancer (http://fightcolorectalcancer.org), and NCCN (National Comprehensive Cancer Network) (www.nccn.com).

### Published Literature Search

A scan of the published medical literature was conducted to address Guiding Question 3. Searches were performed in MEDLINE^®^, Embase^®^, and the Cochrane Library (specifically CENTRAL, DARE, and the HTA Database). The search strategy for MEDLINE^®^ (start date of 1946) is shown in Appendix A.

The DistillerSR^®^ Systematic Review Tool (Evidence Partners Inc., Manotick, ON, Canada) was used to facilitate the screening and study selection process, as follows. Titles and abstracts were screened independently by two reviewers to detect potential articles relevant to the topic. Full-text articles of those marked as potentially relevant were retrieved and screened independently by two reviewers for inclusion or exclusion in the Brief. Disagreements were reviewed and resolved by consensus. Reference lists of included studies were reviewed to identify additional studies.

Published studies, with English-language abstracts, were included in this Technical Brief if they described analytic validity, clinical validity, or clinical utility for GEP test results in patients with stage II (or Duke B) colon cancer. The included studies used GEP assays analyzing RNA (e.g., cDNA or oligonucleotide microarrays) and reported clinical outcome (e.g., cancer recurrence or death) with at least 2 years of followup, as 2 years is the minimum followup time needed to adequately assess whether or not a patient is free of recurrence. In addition, benefit from adjuvant chemotherapy was used as another outcome marker. The data elements abstracted from included articles is listed in Appendix B.

Studies were excluded if they did not describe use of a GEP (multiple genes) or did not provide information that correlated the GEP result with a clinical outcome. Studies that used GEP results for other purposes, such as in the diagnosis of colon cancer or determining cancer stage at the time of surgery were also not included. Studies that did not provide results specific for stage II colon cancer, because they included various stages of cancer or both colon and rectal cancers) were not included in this Brief. However, citations for these studies were noted and are listed in Appendix C.