# Findings

## Description of Proposed Intervention

### Guiding Question 1 What are important aspects of GEPs?

#### What GEP Products are Available for Clinical use in Patients With Stage II Colon Cancer?

As of July 2012, in the U.S., five gene expression profile (GEP) assays are commercially available; one of these GEP assay may also be available through a clinical trial and one is noted for nondiagnostic or research use only (Table 1). These GEP assays are all prognostic indicators.

Table 1 Gene expression assays available for clinical use in stage II colon cancer

Assay | Company | Gene Signature | Specimen Used
ColoPrint^®^ Colon Cancer Recurrence Assay^*^ | Agendia, Inc | 18 Gene Expression Profile (using Agilent microarray) | Fresh tissue or fresh, frozen tissue
ColonPRS^®^+ | Signal Genetics, L.L.C. | 163 Genes | Fresh, frozen biopsies
GeneFx^®^ Colon | Precision Therapeutics | 634 Probe-set signature | Formalin-fixed paraffin embedded tissue
OncoDefender-CRC (colon and rectal cancer) | Everist Genomics | 5 Genes | Formalin-fixed paraffin embedded tissue
Oncotype DX^®^ Colon Cancer Assay | Genomic Health, Inc. | 12 Genes (Seven prognostic and five reference genes) | Formalin-fixed paraffin embedded tissue

* May also be available for use through PARSC Clinical Trial

+ Currently (July 2012) available for nondiagnostic or research use only

These commercially available assays use proprietary approaches to measure RNA using either reverse-transcriptase polymerase chain reactions (PCR) or a gene chip microarray system to determine the GEP result.

#### What Types of Tissue Specimens (e.g., Frozen Tissue) are Analyzed for the GEP?

Two sources of tissue are being used for these assays; either fresh-frozen tissue or formalin-fixed, paraffin-embedded (FFPE) tissue. Either approach is acceptable. Assays that use the FFPE-tissue are generally viewed as more convenient because the FFPE-specimens use tissue from the process used to prepare surgical specimens for routine histological examination. Because RNA is unstable, it degrades in the FFPE-specimens, and therefore these specimens contain less RNA. This approach uses reference genes to adjust for the RNA degradation. Other GEP assays, and especially GEP assays being developed, use fresh, frozen tissue or fresh tissue kept in media such as RNARetain because there is less degradation of the RNA. This approach results in a non-standard approach to specimen-handing, especially for frozen samples, and can lead to problems with obtaining or storing the specimens. As noted in Table 1, three of the available GEP assays use FFPE-tissue. In addition, in many cases, the tissue specimen undergoes microdissection to obtain specimens that have a high proportion of tumor cells (e.g., 80 percent or more). Very little information is provided about tissue handling and processing or about freezing and storage of tumor tissue that is subsequently used for the GEP assay.

#### What is the Test Turnaround Time, That is, how Long Does it Take To Obtain Test Results?

Minimal data were found concerning this question. Information on three of the GEP assays: ColoPrint^®^ Colon Cancer Recurrence Assay and the OncoDefender-CRC assay, indicated (www.agendia.com, and www.everistgenomics.com respectively) that the results of its assay are available within 7 to 10 days following receipt of the tumor sample and Oncotype DX^®^ Colon Cancer assay indicated results are available in 10–12 days (www.oncotypedx.com).

In considering this question about turn-around time, the clinical context for use of the result needs to be considered. The results of the GEP assays in this Technical Brief may provide additional information concerning the decision about administering adjuvant chemotherapy in patients with stage II colon cancer. The discussion with a patient about the benefits and risks of adjuvant chemotherapy usually occurs 3 to 6 weeks after surgery (once final pathology results are known) and the chemotherapy is generally initiated between 4 to 8 weeks after surgery. Thus, test turn-around time of one to two weeks would seem to be acceptable.

Therefore, if the GEP assay is to be useful in clinical care, the turn-around time has to provide results within the time between when a patient with stage II disease is presented with options regarding adjuvant therapy and the time when the adjuvant therapy needs to be started (generally no later than 8 weeks after surgery).

#### What are the Potential Benefits and Harms of This Testing Compared With Current Practice?

The key research questions that must be addressed are whether use of GEP results lead to improved net health outcome and whether use of GEP assays is better than use of alternative prognostic and predictive markers, including both clinical findings as well as other candidate biomarkers, such as microsatellite instability.

As noted in the Background section, currently the decision about administering adjuvant chemotherapy in patients with stage II colon cancer is based on the presence or absence of risk factors, many of which come from detailed histological examination of the tumor. These risk factors help to predict the likelihood of recurrent (metastatic) disease and thus impact the decision regarding adjuvant chemotherapy. Other factors, including the patient’s co-morbid conditions and functional status can impact the recommendations. As also noted previously, with current practice we cannot identify the exact subset of patients with stage II disease who will benefit from adjuvant chemotherapy.

Thus, there are several potential benefits for use of GEP in patients with stage II colon cancer. If the GEP assay can accurately identify stage II patients who are at very low risk (prognostic marker) for a future recurrence of colon cancer; use of adjuvant chemotherapy would likely not be needed. This benefit would be particularly important if these patients are incorrectly classified with current methods as high risk and are given adjuvant chemotherapy.

Another potential benefit for use of a GEP assay is to identify those with stage II colon cancer at high risk of recurrence. Adjuvant chemotherapy may then be recommended in these patients. This may be most useful if the GEP result accurately identified patients who are considered to be at low risk for recurrence with currently used measures and thus do not receive adjuvant chemotherapy. While use of GEP in this way as a prognostic marker does not indicate likelihood of response to adjuvant chemotherapy, this is similar to how decisions about adjuvant chemotherapy are made currently using clinical markers.

An important potential benefit for use of a GEP assay in these stage II patients is to identify those for whom adjuvant chemotherapy using a specific therapeutic regimen provides substantial reduction in the risk of future recurrence of colon cancer and leads to improved survival. This use as a predictive marker is important in that the outcome is improved survival from a specific regimen of adjuvant chemotherapy. Note that a predictive GEP assay might have a different genetic signature than a prognostic GEP assay. If so, the predictive assay would be used if the prognostic result indicated high risk of recurrence. In this situation, the GEP result is correlated with the benefit from adjuvant chemotherapy.

The primary potential harm for use of GEP in these patients is similar to harms with most testing; that is, making decisions about treatment for patients who have false-positive or false-negative results. In particular, incorrectly withholding adjuvant chemotherapy because of the result of a GEP assay in a patient with stage II colon cancer who would benefit from treatment would result in harm. Thus, it is imperative to understand the accuracy (clinical validity) of the GEP assays being evaluated.

#### Is GEP Testing a Replacement or add-on Technology?

While the final answer to this question requires additional research, at the present time this test likely will be an “add-on” technology. That is, the GEP assays are being studied as a better way to identify risk of disease recurrence and/or benefit from adjuvant therapy than existing approaches. The existing approaches generally use information that is routinely obtained from the surgical procedure (presence of bowel perforation) and histological examination of the tumor (perivascular invasion by tumor). Use of the GEP assays will not replace these standard procedures.

With additional research the GEP assays could replace determination of microsatellite instability as a risk marker in stage II cancer. However, this is a theoretical possibility at this time, and this possibility would likely vary among different GEP assays.

### Guiding Question 2 What is the clinical approach for using GEP assays?

#### Are all Patients With Stage II Colon Cancer Included in Studies of GEPs?

There is variability in the clinical studies of GEP assays regarding which patients with stage II colon cancer are included. Some studies include all stage II patients, while others only include those tumors without microsatellite instability.

In addition, GEP assays to predict response to adjuvant chemotherapy should be assumed to apply only to patients receiving the specific drug regimens that were used in deriving and validating the GEP assay. That is, the predictive GEP assays should be assumed to be regimen specific.

#### What is the U.S. Food and Drug Administration (FDA) Status of These Tests?

A search of the U.S. Food and Drug Administration (FDA) Web site did not provide any information regarding the use of the commercially available GEP assays for use in stage II colon cancer.14 Thus, none of these GEP assays has specific approval from the FDA.

However, regulatory oversight for genetic tests is not straightforward. The primary regulatory bodies overseeing genetic tests such as GEPs, in the U.S. are the FDA and the Centers for Medicare and Medicaid Services under the Clinical Laboratory Improvement Amendments of 1988 (CLIA). The FDA addresses the safety and effectiveness of diagnostic tests and the quality of the design and manufacture of these tests, whereas CLIA regulates laboratory personnel qualifications, quality-control procedures, and proficiency testing programs. The FDA has jurisdiction over both laboratory developed tests (LDTs) for use in an in-house laboratory and tests classified as “in-vitro devices” that are distributed to other laboratories as test kits. Historically, the FDA has subjected test kits to premarket review of safety and effectiveness, but not most LDTs. Thus, GEPs marketed as LDTs may enter the U.S. market with analytical validation under laboratory regulations imposed by CLIA but without evidence of clinical validity or utility. If a specific test were to be reviewed by the FDA, the review would evaluate its safety and effectiveness, which implies review of information on at least clinical validity. The GEP assays currently (July 2012) available are being marketed as LDTs.

#### Currently, how Widely Used are These Tests?

Input from Key Informants indicated that currently there is little use of GEP assays in the clinical care of patients with stage II colon cancer; clinical use would be to assist in the decision regarding adjuvant chemotherapy. Key Informants also noted this is an area of great clinical interest and active research with many research presentations at major scientific meetings. Some of the Key Informants expect use rates to increase. The interest in this topic is also likely related to the use of GEP assays in cases of early stage breast cancer. The current availability of five GEP assays (Table 1) seems to also indicate interest in their use for patients with stage II colon cancer.

Input from Key Informants indicated that current standard of care for stage II patients does not include GEP testing. Guidelines of professional societies (National Comprehensive Cancer Network and American Society of Clinical Oncology) have reached a similar conclusion.5, 15 The patient-oriented Web sites of the American Cancer Society, American Society of Clinical Oncology, Cancer.Net, Colon Cancer Alliance, Fight Colorectal Cancer, and NCCN (National Comprehensive Cancer Network) contained variable information about use of GEP assays. While not every site had information, some provided general information about GEP testing while others provided information about specific tests. A summary of the information from those Web sites is found in Table 2.

Table 2 Information about gene expression profile assays in colon cancer from patient-oriented Web sites

Organization | Information Noted
American Cancer Society | No specific information on GEP assays in colon cancer
ASCO (American Society of Clinical Oncology) | Has links to abstracts of ASCO annual meetings No specific information found on GEP assays
Cancer.Net | Item that indicates gene test may predict recurrence risk for colon cancer
Colon Cancer Alliance | Has page on “Oncotype DX^®^ For Stage II Colon Cancer” that includes/links to Resources and Information
Fight Colon Cancer | Lists several news items on developments in use of GEP assays in colon cancer
NCCN (National Comprehensive Cancer Network) | Has Guidelines for Patients: Colon Cancer Does not mention GEP assays

## Evidence Map

### Guiding Question 3 What is the cCurrent evidence for the technology/intervention?

#### Published Literature

The search strategy used to identify published studies for MEDLINE^®^ (start date of 1946 through May 2012) is shown in Appendix A. This strategy was adapted for EMBASE^®^, and the Cochrane Library (specifically CENTRAL, DARE, and the HTA Database). A total of 1,363 citations were identified in the searches. Combined review of the titles and abstracts excluded 1, 154 of the citations. The principal reasons for exclusion at this stage were that a study enrolled only patients with metastatic colon cancer; the patients did not have colon cancer (publications dealing with only rectal cancer were excluded at this stage); the testing involved only a single gene (and thus was not a gene-expression profile); the testing did not analyze RNA; or the testing was chromosome or mutation analysis (rather than gene-expression). Publications that used GEP results for other purposes, such as the diagnosis of colon cancer or determining cancer stage at the time of surgery, were also excluded at this time. Review of the 209 full-text articles identified 20 studies related to the analytical validity, clinical validity, and/or clinical utility in patients with stage II colon cancer. The major reasons for exclusion during full-text review were that specific outcome data for patients with stage II colon cancer were not presented or that the test being studied was not a GEP assay, either because it was a single-gene marker or an assay that did not measure RNA. Therefore, this Brief includes data from 20 studies16–33 that provided primary information on the relationship between GEP results and clinical outcomes, along with information on analytic validity, in patients with stage II colon cancer. Of note, two of these publications19, 28 include datasets with combined information on Stage II colon and rectal cancer; these studies are included here because subsequent validation study19, 26 involved only patients with stage II colon cancer. A list of data elements abstracted from these included studies can be found in Appendix B.

#### What Published and Unpublished Studies, Including Both Derivation and Validation Studies, Have Reported on the Clinical Validity and Clinical Utility for Each of the GEPs for Potential use in Patients With Stage II Colon Cancer? How Extensively Have the Clinical Validity and Clinical Utility of These Tests Been Validated?

##### GEP Assays as Prognostic Markers

The majority of the published studies evaluated use of the GEP assays as a prognostic marker, that is, determining the relationship, clinical validity, between the GEP test result and outcomes such as recurrence of cancer or survival in the population studied. Based on these published studies, information about the state of the science for use of GEP assay as a prognostic marker, that is, relationship between the marker and disease recurrence, in stage II colon cancer is shown in Table 3. The included studies16–20, 22, 23, 25–28, 30–33 described thirteen different GEP assays for this application. Four of the commercially available GEP assays are listed in the first rows in Table 3; the peer-reviewed publication24 for the fifth commercially available assay (OncoDefender-CRC) includes data for patients with both stage I and II colon cancer and is thus not included in Table 3; summary information for that study is provided in the next section.

Table 3 Summary of scientific evidence for gene expression profiles in stage II colon cancer: prognostic—clinical validity and clinical utility

GEP: Name and/or Gene Expression | Initial Derivation: No. CC Pts. | Initial Published Validation | Subq Val: No. Studies | Subq Val: No. Patients | Subq Val: No. Dataset | Subq Val: Study Design | Recurrence | Overall Survival | Re-class Done? | Re-Class Comparison | Clinical Utility | Discrimination Discussed | Account for MSI | Ethnicity
Oncotype DX^®^ Colon Cancer Assay: 12-Gene Prognostic (7 Prognostic and 5 Reference Genes) Derivation: (O’Connell 2010)27 Validation: (Gray 2011)20 | 1,851 | LO | 1 | 1,436 | 1 | RP | •V | •V | | | | | Yes | U.K. sites for validation
ColonPRS^®^: 163-Gene Prognostic Gene Expression Signature (VanLaar 2010)31 | 232 | DS 33(II) 60(T) | | | | | •V
ColoPrint^®^ Colon Cancer Recurrence Assay 18-Gene Prognostic Classifier Derivation:^*^ (Salazar 2011)28 Validation: (Nitsche 2012) 26 | 188 | LO, DS 114(II), 206(T) | 1 | 135 | 1 | RP | •V | | Y N | ASCO | | | Yes
Gene Fx^®^ Colon634 Probe set signature (Kennedy 2011)23 | 215 | LO, DS 144(II) | | | | | •V | •V
23-Gene Signature (Wang 2004)33 Validation: (Barrier 2006)16 | 38 | DS 36(II) | 1 | 50 | 1 | RP | •V
42 Core Gene Classifier^*^ (Eschrich 2005)19 | 78 | LO, DS 32(II), 95(T) | | | | | | •V 26 genes
30-Gene Prognosis Prediction (Barrier 2006)16 | 50 | LO | | | | | • | | | | | | Yes, MSS only
70-Gene Prognostic Predictor (Barrier 2007)17 | 24 | LO | | | | | •
Map7/B2M Gene Expression Ratio (Blum 2008)18 | 22 | DS | | | | | • | •
25 Genes w/in 28 Gene Breast Cancer Prognostic Signature (Wan 2010)32 | 50 | LO, DS 24(II) | | | | | •V
34 Gene Recurrence Classifier (Smith 2010)30 | 55 | DS 57(II) 177(T) | | | | | •V
9 Genes within 12 Gene genomic instability signature (Mettu 2010)25 | 50 | LO | | | | | •
54-Gene Metastasis-prone Signature (Hong 2010)22 | 70 | LO | | | | | • | | | | | | Yes, MSS only | Han Chinese

DS = Different Set of patients; GEP = Gene expression profiles; LO = Leave-out one validation technique; MSI = Microsatellite instability; MSS = Microsatellite stable; Re-class = reclassification; RP = Retrospective-Prospective; Y = Yes; N = No; ASCO = American Society of Clinical Oncology

* Derivation set involved patients with both colon and rectal cancers

Notes: For validation, 32(II) means 32 patients with stage II colon cancer and 90(T) means 90 patients total with various stages of colon cancer

“•” indicates outcome measured; V:Validated with different set of patients; Blank (empty) cells indicate not measured or not addressed

A subsequent, independent validation study was performed on three of the GEP assays shown in Table 3. The twelve-gene Oncotype DX^®^ colon cancer assay was validated in a study of 1,436 patients,20 the 18-gene ColoPrint^®^ assay was validated in a study with 135 patients with stage II colon cancer,26 and the 23-gene signature was validated in a study of 50 patients.16

In evaluating GEP assays, clinical utility is critically important because it shows how use of the assay with individual patients impacts net outcome; that is, it addresses the question “Does use of the GEP assay in clinical care improve overall patient outcome?” None of the studies in Table 3 provide information on the clinical utility with use of the GEP result for prognosis. That is, no studies showed the impact on net health outcome. The change in net outcome with use of the GEP assay could be shown with use of the GEP assay in a prospective clinical trial. Change in net outcome might also be shown with a net reclassification analysis; that is, how use of the GEP to classify the patients in the study with and without the outcome compares with conventional approaches along with linking the changes in classification to the impact on net health outcome. However, just showing that results of a GEP assay can stratify patients into risk groups and that the GEP result is an independent predictor of outcomes does not demonstrate clinical utility. Finally, none of the publications discussed the ability of the GEP result to show discrimination, that is, to classify patients into outcome groups that are clinically distinct.

As shown in Table 3, the first publication was in 2004, the most recent in 2012. The GEPs varied from using 9 genes25 to one that used 634 probes.23 The GEPs were derived from tissue samples from colon cancer patients ranging from 22^18^ to 1,851^20, 27^ (median=55). The potential role of microsatellite instability (MSI) in the study was addressed for four of the profiles (six studies).16, 20, 22, 26–28 This is problematic because MSI status is used in the risk-stratification of patients with stage II colon cancer. Thus, MSI-status needs to be measured and/or taken into consideration in the analysis.

In 2011, Gröne21 reported on the inability to validate the GEP results of Wang (2004)33 and Barrier (2006)16 with an independent sample of 53 patients with stage II colon cancer. However, because of the limited data provided in the publication (only p values from the analysis were provided), this information is not included in Table 3.

In 2009, Jorissen34 reported on a 128-gene signature that was derived using a unique approach and thus this study is not included in Table 3 or Table 4. Instead of determining the GEP from patients with stage II cancer that did or did not develop recurrent disease, this study determined the GEP comparing fresh-frozen tissue specimens from stage A (Stage 1) and stage D (Stage IV) colorectal cancer. The GEP assay was then applied to samples from patients with stages B and C (stages II and III) colorectal cancer to determine if individual tumors were more like stage A or stage D. Validation included applying the GEP assay to an independent set of 99 patients with colon cancer (33 with stage B); the results of the assay did identify two risk groups. No information was provided on clinical utility. In a subsequent publication, Thorsteinsson35 reported that a group of 20 patients with stage II colon cancer were not stratified with use of this GEP assay.

Table 4 Summary of scientific evidence for analytic validity of prognostic gene expression profiles in stage II colon cancer

GEP: Name and/or Gene Expression | Type of Tissue Used | Sample Handling | Technique for GEP | Reliability (Reproducibility) | Time to Report Results
Oncotype DX^®^ Colon Cancer Assay: 12-Gene Prognostic (7 Prognostic and 5 Reference Genes) Derivation: (O’Connell 2010)27 Validation (Gray 2011)20 Analytic Performance (Clark-Langone)36 | Fixed, paraffin-embedded tissue | Microdissected | Reverse transcription-quantitative PCR (RT-qPCR) | 23.6 ± 1.18 (SD) 43.6 ± 1.38 (SD) | 10–12 days
ColonPRS^®^: 163 Gene Prognostic Gene Expression Signature (VanLaar 2010)31 | Fresh-frozen biopsies | | Hybridization with Affymetrix U133 Plus 2.0 | Replicate hybridization done to study inter-laboratory variability | ?
ColoPrint^®^ 18-Gene Signature Derivation: (Salazar 2011)28 Validation: (Nitsche 2012) 26 | Fresh, frozen tissue | | Agendia customized whole-genome high-density microarrays | | 7–10 days
GeneFx^®^ Colon 634-Probe set signature (Kennedy 2011)23 | FFPE Tissue | Tissue section with >50% tumor cells | Amplified product hybridized to Almac Colorectal Cancer DSA on Affymetrix 7G scanner. | | ?
23-Gene Signature (Wang 2004)33 | Fresh, frozen specimens | Total cell population >85% tumor cells | Hybridized to U 133a GeneChip (Affymetrix, Santa Clara, CA) | | ?
42 Core Gene Classifier (Eschrich 2005)19 | Frozen samples | Microdissected so >80% tumor cells | Profiled on The Institute for Genomic Research cDNA arrays. Validation with Affymetrix U133A platform | | ?
30-Gene Prognosis Prediction (Barrier 2006)16 | Fresh tissue, stored in liquid nitrogen | Reviewed for >80% tumor cells | Hybridized to Affymetrix HGU133A Gene Chips | | ?
70-Gene Prognostic Predictor (Barrier 2007)17 | Fresh specimens, stored in liquid nitrogen; Non-neoplastic mucosa | | Hybridized to Affymetrix HGU133A GeneChip | | ?
Map7/B2M Gene Expression Ratio (Blum 2008)18 | Formalin-fixed Paraffin-embedded (FFPE) tissue | | Real-time RT-PCR using PE Biosystems Gene Amp^®^ 7300 or 7500 Sequence Detection System | | ?
25 Genes w/in 28 Gene Breast Cancer Prognostic Signature (Wan 2010)32 | Cases from prior reported series | | Affymetrix U133A array | | ?
34 Gene Recurrence Classifier (Smith 2010)30 | Fresh tissue, flash frozen, stored −80°C | | Hybridized to U133 Plus 2.0 GeneChip Expression Array | | ?
9 Genes w/in 12 Gene genomic instability signature (Mettu 2010)25 | | | Hybridized to Affymetrix U133A arrays | | ?
54 Gene Metastasis-prone Signature (Hong 2010)22 | Fresh tissue, flash frozen w/in 30 minutes, stored at −80°C | Microdissected for tumor cells >90% | Hybridized to Affymetrix U133 Plus 2 Array | | ?

DSA = Disease-specific array; GEP = Gene expression profiles; PCR = Polymerase chain reaction; RT-PCR = real-time polymerase chain reaction; RT-qPCR = real-time quantitative polymerase chain reaction; SD = Standard deviation

Note – Blank indicates not done or not addressed, and “?” indicates uncertain.

The information presented in Table 3 shows that numerous GEP assays have been reported. The small number of patients used to derive many of the GEP assays as well as the large number of genes contained in the assay raises questions about whether subsequent study(s) would validate the initial findings.

#### Was a Reclassification Analysis Performed With Risk Stratification Using GEP When Compared With That Obtained With Standard Risk Factors?

As noted above, none of the studies described the important issue of clinical utility with use of the GEP result for prognosis. No studies showed the change that use of the GEP result would have on overall patient outcomes with a net reclassification analysis; that is, how use of the GEP to classify the patients in the study with and without the outcome compares with standard approaches to classifying these stage II patients and how the change in classification impacts net outcome.

The derivation study for the 18-gene ColoPrint^®^ prognostic classifier reported the net changes in classification of 114 patients with stage II colon and rectal cancer with use of the GEP assay compared to ASCO risk criteria.28 In this study, the GEP assay changed risk groups for 55 patients. No additional detail was provided about the characteristics of patients whose risk category changed. The published validation study of this GEP did not provide data on net reclassification.26

#### What Information is Available Regarding Analytic Validity?

Information related to the analytic validity as well as about the type of tissue used and sample preparation for these 16 GEP assays used for prognostic outcomes is shown in Table 4. Of note, there was limited information provided about the important topic of reproducibility; how repeat assays for the same tumor compare. Clark-Langone et al., reported on the analytic validity of the Oncotype DX^®^ Colon Cancer Assay.36 The authors reported a number of measurements including PCR amplification efficiency, linearity over a range of concentrations, and reproducibility. Precision using two RNA pools for the recurrence score (RS) was 23.6 ± 1.18 (SD: standard deviation) for low RS and 43.6 ± 1.38 (SD) for high RS. As noted earlier, the type of tissue used varies; some used fresh-frozen tissue and other assays used formalin-fixed paraffin-embedded (FFPE) tissue. While it is important to determine the similarities between the assay techniques used in research studies and those that might be used in commercial applications, it is likely too early to make this determination.

Information was not found about the composition of all the commercially available GEP assays. However, there was no overlap in the genes comprising the ColoPrint^®^ assay,28 the OncoDefender-CRC assay,24 and the Oncotype DX^®^ colon cancer assay.36

##### GEP Assays as Predictive Markers

There were few studies on use of GEP assays as predictive markers, that is, relationship between the GEP assay and reduced tumor recurrence (or improved survival) with adjuvant chemotherapy. As noted earlier, this type of marker is very important in identifying improvement from use of adjuvant treatment. Deriving and validating a GEP assay for prediction would require data from comparative studies on use of adjuvant chemotherapy in patients with stage II colon cancer. Information about the state of the science for use of GEP assay as a predictive marker, that is, benefit from adjuvant chemotherapy, in stage II colon cancer is shown in Table 5. No GEP assays are commercially available for this application. A unique 11-gene (6 predictive and 5 reference genes) predictive assay was derived in a group of 816 patients with stage II colon cancer; however, the predictive marker did not validate in an independent cohort of 1,436 patients. As shown in Table 6, this assay used microdissection of fixed, paraffin-embedded tissue during sample preparation, such an approach is often used for GEP assays.

Table 5 Summary of scientific evidence for gene expression profiles in stage II colon cancer: predictive—clinical validity and clinical utility

GEP: Name and/or Gene Expression | Initial Derivation# CC Pts | Initial Pub Validated^a^ | Subq Val # Studies | Subq Val # Patients | Subq Val # Dataset | Subq Val Study Des | Response to Treatment | Chemotherapy | Re-Class Done? | Re-Class Comparison | Clinical Utility | Discrimination | Account for MSI | Ethnicity
11 Gene Predictive (6 Predictive and 5 Reference Genes) Derivation: (O’Connell 2010)27 Validation: (Gray 2011)20 | 816 | LO | 1 | 1,436 | 1 | RP | •NV | FU and LV | | | | | Yes | U.K. sites for validation

GEP = gene expression profiles; LO = leave-out; NV = not successfully validated; subq val = subsequent validation; MSI = microsatellite instability; FU = fluorouracil; LV = leucovorin; RP = retrospective-prospective

a For example, if recurrence rate, how was it determined? (was tissue obtained?)

Note : “•” indicates Yes or included, blank indicates not done or not addressed, and “?” indicates uncertain.

Table 6 Summary of scientific evidence for analytic validity of predictive gene expression profiles in stage II colon cancer

GEP: Name and/or Gene Expression | Type of Tissue Used and Sample Handling | Sample Handling | Technique for GEP | Reliability (Reproducibility) | Time to Report Results
11 Gene Predictive (6 Predictive and 5 Reference Genes) Derivation: (O’Connell 2010)27 Validation: (Gray 2011)20 | Fixed, paraffin-embedded tissue | Microdissected | Reverse transcription-quantitative PCR (RT-qPCR) | | ?

GEP = Gene expression profiles; PCR = Polymerase chain reaction

Note – Blank indicates not done or not addressed, and “?” indicates uncertain.

##### GEP Using MicroRNA

Information about the state of the science for use of a gene expression profile using microRNAs (assays in Table 3 use messenger RNA [mRNA]) as a prognostic marker in stage II colon cancer is shown in Table 7. A profile using 17 microRNAs was derived in a group of 49 patients29; no independent validation has been reported. As shown in Table 8, this assay used fresh, frozen tissue.

Table 7 Summary of scientific evidence for MicroRNAs in stage II colon cancer: prognostic—clinical validity and clinical utility

MicroRNA Profile: Name and/or Gene Expression | Initial Derivation: No. CC Pts. | Initial Publ. Validation | Subq Val: No. Studies | Subq Val: No. Patients | Subq Val: No. Dataset | Subq Val: Study Des | Recurrence | Overall Survival | Re-class Done? | Re-Class Comparison | Clinical Utility | Discrimination Discussed | Account for MSI | Ethnicity
17 MicroRNA Expression Profile (Schepeler 2008)29 | 49 | LO | | | | | • | | | | | | Yes

GEP = Gene expression profiles; LO = Leave-out one validation; No. CC Pts = Number of colon cancer patients; Subq val = Subsequent validation; MSI = Microsatellite instability

Note – “•” indicates Yes or included, blank indicates not done or not addressed

Table 8 Summary of scientific evidence for analytic validity of MicroRNA in stage II colon cancer

MicroRNA: Name and/or MicroRNA Expression | Type of Tissue Used | Sample Handling | Technique for MicroRNA | Reliability (Reproducibility) | Time to report results
17 MicroRNA Expression Profile (Schepeler 2008)29 | Fresh tissue, frozen in liquid nitrogen | | Real-time reverse transcriptase-PCR and in situ hybridization | | ?

PCR = Polymerase chain reaction

Note – “•” indicates Yes or included, blank indicates not done or not addressed, and “?” indicates uncertain.

Table 3 through Table 8 only include information from studies that provided specific results for patients with stage II colon cancer. In some cases, the relationship between the GEP result and clinical outcome(s) was presented only for patients with multiple stages of colon cancer or colon and rectal cancer. One example of publications combining multiple stages of cancer is a study on the five-gene prognostic assay (OncoDefender-CRC).24 In this study by Lenehan and colleagues, a five-gene expression classifier was derived using formalin-fixed paraffin-embedded tissue from 74 patients with colorectal cancer and then validated using an independent sample of 251 patients with stage I and II colon cancer. No data were presented for clinical utility.

A listing of studies that did not provide specific results for stage II colon cancer is provided in Appendix C. Given the clinical differences between patients with various stages of colon cancer and between colon and rectal cancer, this Brief provides no summary information for these studies.

#### What Key Studies are Underway?

- Ongoing clinical trials on the topic from clinicaltrials.gov and other clinical trial registries or systematic reviews.
  The list of clinical trials of potential relevance to this topic is provided in Table 9. These trials were identified by searching clinicaltrials.gov (www.clinicaltrials.gov) and the World Health Organization International Clinical Trials Registry platform (www.who.int/ictrp/en).
  The PARSC (Prospective Study for the Assessment of Recurrence Risk in Stage II Colon Cancer Patients using ColoPrint^®^) study seems of particular interest to this Brief. The study began in September 2008. The enrollment period will be 4 years. It is expected that 1,800 to 2,400 patients will be enrolled in order to obtain 575 analyzable samples from eligible patients with stage II colon cancer. Approximately 25 to 35 sites will be involved worldwide. The aim of the study is to validate the performance of ColoPrint^®^ in estimating 3-year relapse rate. Secondary objectives include comparing the objective risk assessment results from the prognostic profile (ColoPrint^®^) to both the risk assessment based on the American Society of Clinical Oncology criteria, as well as the investigator’s independent assessment. The study will also address the logistics and quality assurance of using ColoPrint^®^ in clinical practice.
- Abstracts published at recent scientific meetings for potential breaking scientific developments.
  The literature review identified eleven published abstracts from recent meetings that are relevant to this topic that were not identified in our search of the published peer-reviewed literature.

Table 9 Ongoing trials for gene expression profiling in colorectal cancer

Name of Study | Status | Sponsor | Trial Number
A Prospective Study for the Assessment of Recurrence Risk in Stage II Colon Cancer Patients Using ColoPrint (PARSC) | Currently recruiting | Agendia | NCT00903565
Study of Biomarkers Using Blood and Tissue Samples From Patients With Colorectal Cancer or Colorectal Polyps and From Patients Without Polyps (Primary objective is to predict risk of colorectal cancer [CRC]; a secondary objective is to predict response to therapy for various stages of CRC.) | Currently recruiting | Indiana University National Cancer Institute (NCI) | NCT00898378
A Prospective Study of Pharmacogenetic Factors and Gene Expression Profile (This is a parallel study to an RCT of modified FOLFOX-6 as adjuvant therapy in stage II/III colon cancer. This might provide predictive information.) | Currently recruiting | Samsung Medical Center, Seoul | NCT01472601

RCT = Randomized controlled trial

In 2010, Adams and colleagues reported on a 32-probe set signature (Predictor C) derived from a cohort of 55 patients with colorectal cancer.37 This GEP was then evaluated on another set of 164 patients, 90 of whom had stage II cancer. The GEP result was associated with recurrence. Many additional details need to be ascertained for this study, including whether or not patients with rectal cancer were included in this cohort.

In 2011, Venook et al., reported the second independent validation of the twelve-gene signature (Oncotype DX^®^ colon cancer assay) with samples of patients from the CALGM 9581 study of adjuvant chemotherapy in stage II colon cancer.38 The GEP results were validated for predicting risk of recurrence, including in patients with T3 tumors who did not have microsatellite instability. No additional information was provided on clinical utility.

In 2012, Cartwright and colleagues presented preliminary results from a survey of practicing oncologists on recommendations for adjuvant chemotherapy with use of the Oncotype DX^®^ colon cancer test.39 These results were noted as preliminary and additional details may become available. Data from this descriptive, survey-based approach is not sufficient to demonstrate the clinical utility of GEP testing.

In 2012, Tabernero and colleagues presented results of a validation study using ColoPrint^®^ with a pooled set of 320 patients with stage II cancer.40 The abstract discussed reproducibility and stability of the assay as well as clinical validity. Additional details are needed about this study, including whether or not this was only patients with colon cancer. (The initial ColoPrint^®^ studies included stage II patients with both colon and rectal cancer.28) In addition, details about potential overlap between these 320 patients and patients reported in other publications and presentations with ColoPrint^®^ need to be clarified.

In 2012 at the ASCO Annual Meeting, O’Connell et al., reported another independent validation of the twelve-gene signature (Oncotype DX^®^ colon cancer assay) with samples of patients from the NSABP C-07 study of fluorouracil (FU) and FU plus oxaliplatin in stage II/III colon cancer.41 The GEP results were validated for predicting risk of recurrence, including in patients with stage II disease. No information was provided on clinical utility.

In 2012 at the ASCO Annual Meeting, Roth et al., reported results for validation of both the Genomic Health and Veridex risk scores with gene expression data from 580 stage III and 108 stage II colon cancer patients from the PETACC-3 trial.42 Risk scores from both profiles were significantly associated with relapse-free survival in both the stage III and stage II cohorts. For stage III, the highest effect size was a combined model that included both risk scores as well as T-stage, N-stage and MSI status. No information was included related to clinical utility.

In 2012 at the ASCO Annual Meeting, Budinska reported on the identification and validation of five sub-types of colorectal cancer based on clinic-pathological variables and molecular (expression) markers.43 The subtypes had significant differences in survival. Additional detail is needed about the classification as well as specific information for Stage II colon cancer patients.

In 2012 at the ASCO Annual Meeting, Mambo et al., reported on using a set of 30 microRNAs to discriminate among 118 stage IIA colon cancers who did and did not have a recurrence.44 No further validation was reported. Many additional details need to be ascertained for this study, including the composition of the profile.

Also at the 2012 ASCO Annual Meeting, Salazar et al., presented a validation study using the 18 gene ColoPrint^®^ with a pooled set of 320 patients with stage II colon cancer.45 The abstract discussed the relationship between the GEP result and relapse-free survival for both all stage II patients and for the subset of stage II patients with T3 tumors and without MSI-H status. No information was provided about clinical utility. Details about potential overlap between these 320 patients and patients reported in other publications and presentations with ColoPrint need to be clarified.

At this 2012 ASCO Annual Meeting Salazar et al., presented a status report on the PARSC trial using ColoPrint^®^ discussed above.46 The abstract noted that 340 eligible stage II colon cancer patients had been enrolled; the target enrollment for this group is 575 patients.