# Background

## Stage II Colon Cancer

Colon cancer is a common malignancy affecting both women and men. In 2012, it is expected to be the fourth most commonly diagnosed cancer (after prostate, breast, and lung cancer) with an estimated 103,170 new cases and, combined with rectal cancer, is the second most common cause of cancer deaths (after lung cancer) with 51,690 deaths.1

The most important prognostic factor for colon cancer is stage at diagnosis. About 40 percent of patients with colon cancer are initially diagnosed with stage I disease (these localized tumors do not invade through the muscularis propria). Stage I disease has a 5-year survival rate of over 95 percent.2 Five-year survival rates for patients diagnosed with stage II disease are between 58 and 83 percent. Stage II colon cancer is characterized by full-thickness tumor invasion of the bowel wall and the absence of lymph node and distant metastases. Stage II disease is now subdivided into IIA (T3 tumors that invade through the muscularis propria into the pericolorectal tissues), IIB (T4a tumors that directly penetrate to the surface of the visceral peritoneum), and IIC (T4b tumors where tumor directly invades or is adherent to other organs or structures).3 The relative 5-year survival rate for stage II T4a tumors is higher than for T4b lesions.4 Stages III and IV have a worse prognosis.

A number of negative prognostic factors, that is, factors associated with increased risk of recurrence, have been identified in stage II disease including T4 tumors (which tend to be large); obstruction or bowel perforation at initial diagnosis; an inadequately low number of assessed lymph nodes from surgery (12 or fewer); poorly differentiated histology, vascular, lymphatic, and perineural invasion; a high preoperative level of carcinoembryonic antigen; and the presence of indeterminate or positive resection margins.2, 5

Most patients with stage II colon cancer are cured with surgery alone; however, 25 to 30 percent of those with resected stage II disease will develop recurrence or die from their disease. In this group, adjuvant chemotherapy may produce a small improvement in overall survival when compared with surgery alone, and it may afford a small reduction in the risk of disease recurrence. In a 2010 review, Midgley et al. commented, “[W]e have to treat 100 stage II patients to cure 3 or 4, while accepting that up to 40 percent of those treated will suffer significant toxicity….”6 Thus, routine use of adjuvant therapy is usually recommended only in subgroups with stage II disease that may be at higher than average risk for recurrence, such as those whose initial diagnosis is complicated by bowel perforation. For patients where a decision is made to administer adjuvant chemotherapy, an additional decision has to be made about the specific adjuvant regimen that will be used. Identifying the individuals in whom the potential benefits of chemotherapy outweigh the risks is challenging. The current system to assess recurrence risk using the prognostic factors noted above (e.g., a T4 tumor) may be inadequate for determining individual risk. To that end, advances in molecular and genomic medicine, such as gene expression profiling, may improve the clinician’s ability to assess individualized risk and predict response to adjuvant therapy, as long as the test results provide new information that is clinically valid and useful.

## Gene Expression Profiles

Gene expression profiles (GEPs), also known as gene expression patterns or signatures, measure the activity of “expression” of multiple genes using a single sample. Gene expression results from DNA transcription into messenger RNA (mRNA); mRNA then serves as the template for protein synthesis. Gene expression is determined by analyzing RNA in the sample, generally using either reverse transcription quantitative polymerase chain reaction or DNA microarrays. GEP tests use defined protocols to evaluate the specimens to be analyzed: preparing the RNA samples, copying into DNA, normalizing the raw expression measurements, and computing summary results (summary indices). Data from a GEP test can provide information about a cell’s type, its current state of activity, and its local environment.

This Brief will focus on the use of GEP tests for both prognostic and predictive outcomes. For the purposes of this Technical Brief, prognostic outcomes relate to disease prognosis such as recurrence of tumor or survival. The prognostic outcome often assesses disease recurrence over time (usually over 3 to 5 years) and is generally measured by disease-free survival. In contrast, use of GEP assays for predictive outcomes is different. This use correlates the GEP result with benefit (reduced recurrence rate and improved survival) from adjuvant chemotherapy. Predictive assays are especially important in that their use could result in improved survival.

Predicting the two types of outcomes may require different GEP signatures. A GEP signature that is found to be accurate for identifying prognosis may not be accurate for predicting benefit from adjuvant therapy. Similarly, an accurate predictive GEP signature may not provide accurate prognostic information. In addition, predictive GEP signatures may only apply to the adjuvant regimen for which they were studied.

According to Midgley et al. “There are good examples of gene expression profiles being used to improve disease classification in lymphoma and breast cancer and aid in determination of prognosis in breast cancer.”6 Using GEP tests could improve the current staging system for colon cancer. However, in a 2009 publication, based on eight cohorts from six studies, Lu et al. noted that existing GEP tests produced sufficiently high false-positive and false-negative rates to preclude routine use and commented that additional validation studies were needed.7 GEP tests were found to be in various stages of development for use in colon cancer. Given the additional studies on tests reported in that publication and the emergence of new tests, followup of the Lu publication with a Technical Brief is warranted.

### Confounding Factors

There are other factors that can impact disease outcomes and test interpretation that will be mentioned briefly. First, a number of publications and reviews, for example a recent review by Vilar and Gruber,8 provide information on the implications of microsatellite instability, also known as mismatch repair (MMR) deficiency, in colon cancer. The data indicate that MMR deficiency (high microsatellite instability, MSI-H) may identify a small (15–20 percent) population of patients with stage II disease who may derive no benefit or may even experience deleterious effects from adjuvant fluorouracil/leucovorin (FU/LV) -based chemotherapy.8 Colonic malignancies with these characteristics, that is, MSI-H, often demonstrate improved disease-free survival. MSI testing is widely available and used along with clinical risk factors to help make decisions about adjuvant chemotherapy in patients with stage II colon cancer. Thus, it is important that published reports on GEP tests in colon cancer treatment decisionmaking specifically comment on whether (and how) they measured MSI status and how they took this into account in their analysis. As an example, the GEP test might be studied only after patients with MSI-H tumors are excluded.

The adjuvant chemotherapy regimen used when studying GEP assays is another confounding factor. Over the last decade, the schedule and duration of adjuvant chemotherapy in treating colon cancer has changed from a 12-month course of bolus FU and levamisole combination to a 6-month course of either infusion FU or an oral fluoropyrimidine such as capecitabine with or without oxaliplatin. Thus, it will be important to note, as suggested by Tabernero and Baselga9 the chemotherapy regimen(s) for which response was predicted. At present, few studies have addressed use of GEP assays for predicting response to adjuvant therapy. If predictive GEP assays are developed, their use should not be generalized to other regimens.

A recent publication by Gerlinger and colleagues10 reported intratumor heterogeneity and underestimation of the tumor genomic landscape from analysis of multiple samples from patients with primary renal carcinomas and metastatic sites. The heterogeneity included finding gene-expression signatures of both good and poor prognosis in different regions of the same tumor. The possibility of having similar findings of heterogeneity in stage II colon cancer may need to be studied, especially if results from initial GEP studies are not successfully validated.

## Scope of Report

Because the topic of this Brief is GEP testing and GEP is based on results from expression of multiple genes, this Brief does not include reports for expression of single genes. This report also excludes studies of single or multiple genetic mutations. Furthermore, given current knowledge and the complexity of this clinical situation, it seems unlikely that a single gene marker would provide accurate prediction. These single-gene markers may be used to predict response to chemotherapy, prognosis, potential for chemotherapy-related adverse events, or chemotherapy-related dose adjustments, but are not included in the scope of this Brief. New assays that measure RNA to detect tumor cells are also beyond the scope of this Brief. Since the topic of this Brief is patients with stage II colon cancer, publications on the use of GEP for other stages of colon cancer, or for both colon and rectal cancer, will not be included, unless the publication presents information on patients with stage II colon cancer separately. While the term “colorectal cancer” is often used and reports may combine these cases, because of the different approach to surgical and adjuvant therapy of rectal tumors, this Brief on GEP in colon cancer excluded studies with combined analysis of colon and rectal malignancies.

Thus, GEP testing of patients following surgical resection of stage II colon cancer has potential benefit related to prognosis (recurrence) and also related to prediction (benefit from adjuvant therapy), but the magnitude is unknown. Identifying patients who do not need adjuvant chemotherapy because of very low risk of recurrence or predicted lack of benefit from adjuvant chemotherapy would improve the net health outcome by avoiding treatment-related adverse effects. On the other hand, introducing routine testing without a clear understanding of benefits and risks could result in those who would benefit from adjuvant therapy not receiving it. This Technical Brief provides an overview of the “state of the science” for the use of GEP testing in patients with stage II colon cancer. This Brief will not list or synthesize study results. However, the conceptual framework and uncertainties identified in this Brief can inform future comparative effectiveness research.

## Guiding Questions

### Guiding Question 1 What are important aspects of GEPs?

- What GEP products are available for clinical use in patients with stage II colon cancer?
- What types of tissue specimens (e.g., frozen tissue) are analyzed for the GEP?
- What is the test turn-around time, that is, how long does it take to obtain test results?
- What are the potential benefits and harms of this testing compared with current practice?
- Is GEP testing a replacement or add-on technology?

### Guiding Question 2 What is the clinical approach for using GEP assays?

- Are all patients with stage II colon cancer included in studies of GEPs?
- What is the U.S. Food and Drug Administration (FDA) status of these tests?
- Currently, how widely used are these tests?

### Guiding Question 3 What is the current evidence for the technology/intervention?

- What published and unpublished studies, including both derivation and validation studies, have reported on the clinical validity and clinical utility for each of the GEPs for potential use in patients with stage II colon cancer?
- How extensively have the clinical validity and clinical utility of these tests been validated?
- Was a reclassification analysis performed with risk stratification using GEP when compared with that obtained with standard risk factors?
- What information is available regarding analytic validity?

### Guiding Question 4 What important issues are raised by using GEP testing for stage II colon cancer?

- What are the key unresolved or controversial issues with using GEP testing in patients with stage II colon cancer?
- What are the implications of the current level of diffusion and/or further diffusion of this technology/intervention given the current state of the evidence?
- What key studies are currently underway? What are the important questions for future research?